# Acknowledgments

An extensive review of the evidentiary research and practice literature on a subject such as the one represented by this guideline is a collaborative venture requiring dedicated participation and the skills of many people. One can only attempt to adequately thank these individuals in a forum such as this.

On behalf of CSAP, I would like to express our deep gratitude to Dr. Karol Kumpfer and Dr. José Szapocznik, co-chairs, and members of the Expert Panel for their hard work and dedication in systematizing and synthesizing the evidence on the role of family in substance abuse prevention. The panel's vision in adding sections on emerging strategies and collateral research will be particularly useful to both practitioners and researchers. Of course, throughout this process, the leadership and guidance of the PEPS Planning Group has been invaluable. Both the Planning Group and the Expert Panel reviewed several drafts of the guideline, and their efforts are reflected in the final version. We would also like to acknowledge the contributions of the Federal Resource Panel in sharpening the focus of the guideline and for its assistance in accessing fugitive literature.

Many researchers and practitioners in the field reviewed the guideline and provided valuable comments. We believe that their incorporation has substantially improved the final product. Thanks are also due to staff in various CSAP divisions who reviewed successive versions. Special thanks are due to Tom Vischi, Mark Weber, and Bob Denniston for their extensive review and comments. I would be seriously remiss if I did not acknowledge the ongoing support of Dr. Ruth Sanchez-Way, director, Division of State and Community Prevention Systems.

Last but not least, I want to express my deep appreciation to the staff at Birch & Davis Associates, Inc., who drafted the guideline documents and tirelessly reworked them as they passed through various stages of review. The contribution of EEI Communications in final copyediting, production, and quality control is also sincerely appreciated. Executive Editor