# Foreword

The Center for Substance Abuse Prevention in the Substance Abuse and Mental Health Services Administration (CSAP/SAMHSA) is committed to enhancing prevention activities as planned and implemented by federally funded State agencies and community-based organizations across the country. Through a participatory process involving policymakers, researchers, program managers, and practitioners, the Prevention Enhancement Protocols System (PEPS) is generating products that can substantially improve planning and management of prevention programs, consolidate and focus prevention interventions, and potentially serve as the foundation for prevention studies.

CSAP selected the topic of family-centered prevention approaches because problems of substance abuse among adolescents are pervasive, serious, and usually embedded in multiple issues of adolescent antisocial behavior relating to mental health, delinquency, violence, poverty, and parental and family incapacities. Additionally, etiological and intervention research is increasingly demonstrating how adolescent problems of antisocial behavior have roots in the family's structure and the greater community in which the family exists. On both the national and local levels, government, communities, and organizations are interested in finding ways to support families more effectively in their efforts to meet the needs of their children.

This guideline is designed for broad use. Its intended audiences include not only State substance abuse agencies but also national, State, and local organizations that address issues relating to children and families, such as substance abuse, delinquency, child health and welfare, and family support. It is a practical, detailed guide for considering the advantages and disadvantages of specific interventions and for planning prevention initiatives in the community.

The most important aspect of PEPS is the use of systematic protocols to prepare guidelines such as this one. Ultimately, the overarching methodological accomplishments of PEPS may have far greater influence than any single guideline, for they will have given birth to a tradition of development and dissemination of science-based recommendations for the substance abuse prevention field.

Nelba Chavez, Ph.D. Administrator SAMHSA

Karol Kumpfer, Ph.D., Director Center for Substance Abuse Prevention,SAMHSA