# Introduction

The Center for Substance Abuse Prevention (CSAP) created the Prevention Enhancement Protocols System (PEPS) to systematically identify current knowledge on prevention programs and to develop recommendations to guide and strengthen State prevention efforts. Under the PEPS program, panels of prevention experts have, for the first time, organized research and practice evidence on effective prevention programs into a set of guidelines and recommendations that meet the needs of practitioners. To date, one other PEPS guideline has been developed: Reducing Tobacco Use Among Youth: Community-Based Approaches. All of the PEPS documents will be accessible through CSAP's World Wide Web site at http://www.health.org.

Each guideline topic is presented in a set of three documents:

1. A comprehensive reference guide that describes in full the substance abuse topic to be evaluated, reviews research and practice information on the prevention approaches used to address the problem, analyzes the effectiveness of these approaches, discusses lessons learned, suggests a program design and method of implementation, and gives recommendations of the Expert Panel on developing effective prevention programs and designing research
2. A practitioner's guide that distills the guideline into an implementation-directed summary
3. A community guide, in brochure form, that practitioners may use to illustrate the rationale for their proposed prevention plans and to solicit community involvement and support

The practitioner's guide is a unique planning tool. It allows practitioners to:

1. Choose from among proven strategies and approaches to develop their own prevention programs
2. Learn to use a risk factor/protective factor approach to identify problems, collect data, and develop, carry out, and evaluate programs
3. Strengthen program effectiveness by using the "Developing and Delivering Family-Centered Approaches" section
4. Benefit from the evidence-based "Lessons Learned" drawn from the review and analysis of prevention research and practice evidence
5. Benefit from the "Recommendations for Practice" based on the expertise of the PEPS Expert Panel as well as the review of the research and practice evidence