# A Request to Readers

Based on comments received from users of the first guideline, Reducing Tobacco Use Among Youth: Community-Based Approaches, several significant changes have been made in the structure and presentation of this publication. CSAP actively seeks a continuing dialogue with its constituents on the extent to which they find this series useful and the ways in which future guidelines may be improved. Therefore, comments are actively solicited for inclusion in revisions of this guideline or in production of future guidelines. They should be referred to PEPS Program Director, Division of State and Community Systems Development, Center for Substance Abuse Prevention, SAMHSA, 5600 Fishers Lane, Rockwall II, Rockville, MD 20857.