# Panel of Experts Leading the Development of the Guideline Preventing Substance Abuse Among Children and Adolescents: Family-Centered Approaches

- Karol L. Kumpfer, Ph.D., Chair
- José Szapocznik, Ph.D., Co-chair
- Richard Catalano, Ph.D.
- Richard R. Clayton, Ph.D.
- Howard A. Liddle, Ed.D.
- Robert McMahon, Ph.D.
- Joyce Millman
- Maria Elena V. Orrego, M.A.
- Nila Rinehart
- Iris Smith
- Richard Spoth, Ph.D.
- Marilyn Steele, Ph.D.