# Research Studies and Practice Cases

The following references are the research studies and practice cases that were analyzed to determine the level of effectiveness of the three prevention approaches. They have been grouped according to prevention approach.

## Parent and Family Skills Training

### Research Evidence

Aktan, G. B., Kumpfer, K. L., & Turner, C. W. (in press).International Journal of the Addictions
Anastopoulos, A. D., Shelton, T. L., DuPaul, G. J., & Guevremont, D. C. (1993).Journal of Abnormal Child Psychology, 21
Arnold, J. E., Levine, A. G., & Patterson, G. R. (1975).Journal of Consulting and Clinical Psychology, 43
Bank, L., Marlowe, H., Reid, J. B., Patterson, G. R., & Weinrott, M. R. (1991).Journal of Abnormal Child Psychology, 19
Baum, C. G., & Forehand, R. (1981).Behavior Therapy, 12
Bernal, M. E., Klinnert, M. D., & Schultz, L. A. (1980).Journal of Applied Behavior Analysis, 13
Catalano, R. F., Haggerty, K. P., Gainey, R. R., Hoppe, M. J., & the Social Development Research Group. (1995).Reducing parental risk factors for children's substance abuse: Preliminary outcomes with opiate-addicted parents
Dishion, T. J., & Andrews, D. W. (1995)Journal of Consulting and Clinical Psychology, 63,
Dubey, D. R., O'Leary, S. G., & Kaufman, K. F. (1983).Journal of Abnormal Child Psychology, 11
Dumas, J. E. (1984).Journal of Consulting and Clinical Psychology, 52
Family Resource Coalition. (1996).Guidelines for family support practice.
Felner, R. D., Brand, S., Erwin Mulhall, K., Counter, B., Millman, J. B., & Fried, J. (1994).Journal of Primary Prevention, 15
Fleischman, M.J. (1981).Journal of Consulting and Clinical Psychology, 49
Forehand, R., & Long, N. (1988).Advances in Behaviour Research and Therapy, 10,
Guerney, L. (1977).. American Journal of Community Psychology, 5
Guerney, L. F., & Wolfgang, G. (1981).. Journal of Clinical Child Psychology, 10
Horn, W. F., Ialongo, N. S., Pascoe, J. M., Greenberg, G., Packard, T., Lopez, M., Wagner, A., & Puttler, L. (1991).. Journal of the American Academy of Child and Adolescent Psychiatry, 30
Hughes, R. C., & Wilson, P. H. (1988).. Child and Family Behavior Therapy, 10
Ialongo, N. S., Horn, W. F., Pascoe, J. M., Greenberg, G., Packard, T., Lopez, M., Wagner, A., & Puttler, L. (1993).Journal of the American Academy of Child and Adolescent Psychiatry, 32
Institute of Medicine. (1994).Reducing risks for mental disorders: Frontiers for preventive intervention research
Kazdin, A. E., Siegel, T. C., & Bass, D. (1992).Journal of Consulting and Clinical Psychology, 60
Knapp, P. A., & Deluty, R. H. (1989).Journal of Consulting and Clinical Psychology, 18
Kosterman, R., Hawkins, J. D., Spoth, R., Haggerty, K. P., & Zhu, K. (1995).Preparing for the Drug-Free Years: Effects on videotaped family interactions
Kumpfer, K. L., & DeMarsh, J. P. (1987).Prevention services for children of substance-abusing parents
Kumpfer, K. L., Turner, C. W., & Palmer, S. (1991).YCOSA Black Parenting Project: Third and fourth year evaluation report
Long, P., Forehand, R., Wierson, M., & Morgan, A. (1994).32
McMahon, R. J., Forehand, R., & Griest, D. L. (1981).Journal of Consulting and Clinical Psychology, 49
Myers, H. F., Alvy, K. T., Richardson, M., Arrington, A., Marigna, M., Huff, R., Main, M., & Newcomb, M. (1990).The Effective Black Parenting Program: A control research study with inner-city black families.
Patterson, G. R. (1974).Canadian Psychiatric Association Journal, 19
Patterson, G. R. (1975).Applications of behavior modification
Rogers, T. R., Forehand, R., Griest, D. L., Wells, K. C., & McMahon, R. J. (1981).Journal of Clinical Child Psychology, 10
Santisteban, D. A., Szapocznik, J., Perez-Vidal, A., Kurtines, W. M., Murray, E. J., & LaPerriere, A. (in press).Journal of Family Psychology
Spoth, R., & Redmond, C. (1995). "A theory-based model of protective parenting processes incorporating intervention attendance effects." Unpublished manuscript, Social and Behavioral Research Center for Rural Health, Iowa State University, Ames, Iowa.
Spoth, R., Redmond, C., Haggerty, K., & Ward, T. (1995).Journal of Marriage and the Family, 57
Szapocznik, J., Santisteban, D., Rio, A., Perez-Vidal, A., Kurtines, W. M., & Hervis, O.E. (1986).Hispanic Journal of Behavioral Sciences, 8
Szapocznik, J., Santisteban, D., Rio, A., Perez-Vidal, A., Santisteban, D., & Kurtines, W. M. (1989).Hispanic Journal of Behavioral Sciences, 11
Thompson, R. W., Grow, C. R., Ruma, P. R., Daly, D. L., & Burke, R. V. (1993).Family Relations, 42
Tremblay, R. E., McCord, J., Boileau, H., Charlebois, P., Gagnon, C., Le Blanc, M., & Larivee, S. (1991).Psychiatry, 54
Wahler, R. G., Cartor, P. G., Fleischman, J., & Lambert, W. (1993).Journal of Abnormal Child Psychology, 21
Webster-Stratton, C. (1984).. Journal of Consulting and Clinical Psychology, 52
Webster-Stratton, C. (1990a).Journal of Abnormal Child Psychology, 18
Webster-Stratton, C. (1990b).. Journal of Clinical Child Psychology, 19
Webster-Stratton, C., Kolpacoff, M., & Hollinsworth, T. (1988).. Journal of Consulting and Clinical Psychology, 56
Webster-Stratton, C., Kolpacoff, M., & Hollinsworth, T. (1989).Journal of Consulting and Clinical Psychology, 57
Wolchik, S. A., West, S. G., Westover, S., Sandler, I. N., Martin, A., Lustig, J., Tein, J. Y., & Fisher, J. (1993).American Journal of Community Psychology, 21

### Practice Evidence

- The Communication and Parenting Skills program. Milwaukee, Wisconsin.
- The Creating Lasting Impressions program of the Council on Prevention and Education: Substances. Louisville, Kentucky.
- The Families in Focus program of Cottage Program International. Salt Lake City, Utah.
- The Families and Schools Together program of Family Service. Madison, Wisconsin.
- The Kansas Family Initiative of the Kansas Department of Social and Rehabilitation Services. Topeka, Kansas.
- The Nurturing Program for Parents and Children. Eau Claire, Wisconsin.
- The Parenting for Prevention program of the King County Department of Alcohol and Substance Abuse Services. Seattle, Washington.

### Family In-Home Support

Berry, M. (1992).Social Work, 37
Borduin, C. M., Mann, B. J., Cone, L. T., Henggeler, S. W., Fucci, B. R., Blaske, D. M., & Williams, R. A. (1995).Journal of Consulting and Clinical Psychology 63,
Haapala, D. A., & Kinney, J. M. (1988).. Criminal Justice and Behavior, 15
Henggeler, S. W., Melton, G. B., & Smith, L. A. (1992).Journal of Consulting and Clinical Psychology, 60
Henggeler, S. W., Melton, G. B., Smith, L. A., Schoenwald, S. K., & Hanley, J. H. (1993).Journal of Child and Family Studies, 2
Lutzker, J. R., & Rice, J. M. (1987).Journal of Family Violence, 2
Lutzker, J. R., Wesch, D., & Rice, J. M. (1984).Advances in Behaviour Research and Therapy, 6
Walton, E., Fraser, M. W., Lewis, R. E., Pecora, P. J., & Walton, W. K. (1993).Child Welfare, 72

### Family Therapy

Alexander, J. F., & Parsons, B. V. (1973).Journal of Abnormal Psychology, 81
Barton, C., Alexander, J. F., Waldron, H., Turner, C. W., & Warburton, J. (1985).American Journal of Family Therapy, 13
Gordon, D. A., Arbuthnot, J., Gustafson, K. E., & McGreen, P. (1988).American Journal of Family Therapy, 16
Henggeler, S. W., Rodick, J. D., Borduin, C. M., Hanson, C. L., Watson, S. M., & Urey, J. R. (1986).Developmental Psychology, 22
Klein, N. C., Alexander, J. F., & Parsons, B. V. (1977).Journal of Consulting and Clinical Psychology, 45
Mann, B. J., Borduin, C. M., Henggeler, S. W., & Blaske, D. M. (1990).Journal of Consulting and Clinical Psychology, 58
McPherson, S .J., McDonald, L. F., & Ryer, C. W. (1983).Juvenile & Family Court Journal, 34
Santisteban, D. A., Coatsworth, J. D., Perez-Vidal, A., Mitrani, V., Jean-Gilles, M., & Szapocznik, J. (1995).Brief structural/strategic family therapy with African American and Hispanic high-risk youth.
Springer, J. F., Phillips, J. L., Phillips, L., Cannady, L. P., & Kerst-Harris, E. (1992).Journal of Community Psychology
Szapocznik, J., Murray, E., Scopetta, M., Hervis, O., Rio, A., Cohen, R., Rivas-Vazquez, A., Posada, V., & Kurtines, W. (1989).Journal of Consulting and Clinical Psychology, 57