# An Afterword: Emerging Areas Of Research And Practice

Two issues of interest to practitioners have not been included in this guide's review of research and practice. These issues are the constructs of resilience and family support. Many may wonder why two prevention approaches and strategies that are widely discussed and often funded are not included in the reference guide or this practitioner's guide. The reason is that these approaches did not meet the rigorous criteria used to select approaches: an ample body of research and/or practice evidence sufficient to permit a thorough analysis. For both of these strategies, the research evidence is in the early stages.

## The Construct of Resilience

For the purposes of this guide, resilience is defined as either of the following capacities of children (Herrenkohl, Herrenkohl, and Egolf 1994; Luthar 1991; Luthar and Cushing, in press; Turner, Norman, and Zunz 1993):

- The capacity to recover from traumatic life events and restore or improve family functioning. Traumatic life events include the death of a parent, divorce, sexual abuse, and homelessness.
- The capacity to withstand chronic stress and yet sustain competent functioning. Examples of chronic stress are extreme poverty, alcoholic parents, chronic illness, and ongoing domestic or neighborhood violence.

Most resilience researchers agree that resilience involves an interaction among characteristics of the child, the family, and community environments and exposure to adverse circumstances, especially at an early age. However, intervention-based studies are distinctly lacking, so little is known about how these elements interact. Vital questions remain:

- To what extent does resilience rely on and build on biological traits as opposed to learned patterns of behavior?
- Can everyone learn to be resilient, or must certain conditions be present?

## The Construct of Family Support

The driving force behind the family support construct is the conviction that it is the responsibility of family-helping programs and resources to go beyond preventing problems to supporting the optimum development of the capacities that are inherent in all families. This approach is often called "empowerment." Vital assumptions are that the primary responsibility for the development and well-being of children lies within the family, that family services should be rooted in community support systems, and that the role of help-giving agencies is to become partners with families in problem solving (Family Resource Coalition 1996).

Researchers and practitioners who evaluate family support interventions believe that the traditional evaluation approaches are insufficient. They contend that family support research should involve participants in research design and implementation and employ methods that make them stakeholders in evaluation goals and results.

Recent and ongoing research efforts include the following:

- Identifying the importance of using informal resources to help families
- Determining how a family's style of functioning affects its capacity to cope and promote positive growth
- Describing the effects that various modes of helping might have on an individual's ability to become more independent

A general problem in the development of a body of knowledge about family support has been the lack of data sources and information about family and community strengths and assets. Most of the data about families describe either neutral or deficit information, problems, and needs. Until more data are collected and analyzed, it will be difficult to identify which strengths and assets are most useful for helping families achieve optimum results.

## Final Thoughts About Resilience and Family Support

Interventions based on resilience and family support offer program options that might be more effective and less expensive than traditional treatment or deficit-focused strategies. As practitioners experiment with interventions that make intuitive sense and address the problems they see each day, the challenge for research is to keep pace with practice by:

- Further defining these constructs
- Developing accurate measures
- Incorporating evaluation processes that include participants
- Assembling the findings into an integrated body of evidence

This points to many opportunities for researchers and practitioners to work together to determine what works and subsequently increase the impact of interventions using these constructs.