# Conclusion

This practitioner's guide is intended to be brief and simple. For much greater detail concerning the analysis of the three prevention approaches, recommendations for practice, guides for program development and delivery, and emerging areas of research and practice, see the reference guide.

Practitioners face many challenges in their efforts to intervene with families to prevent substance abuse in their children. Despite the complexity of the challenges, a growing body of research and practice literature has documented successful strategies for family-centered interventions. For the first time, information on these strategies and interventions has been brought together in a systematic analysis of their effectiveness. The resulting guidelines are designed to be clear, realistic, and easy to use. It is hoped that they will help develop markedly more effective family-centered approaches to prevent substance abuse among children and adolescents.