# Program Development and Delivery of Family-Centered Approaches

The reference guide from which this document is derived, Preventing Substance Abuse Among Children and Adolescents: Family-Centered Approaches, has a detailed and extremely helpful presentation on program development, delivery, and evaluation. Practitioners are encouraged to examine that section of the full guideline very carefully.

The material presented in this section contains:

1. A detailed planning table entitled "Specific Tasks and Activities of Program Development." The table lists the basic activities and tasks for the four steps of program development:
  a. Assessment
  b. Planning
  c. Delivery
  d. Evaluation
2. Special planning issues for family-centered approaches include:
  a. A discussion on ways to relate demographic information to risk and protective factors and to table 2, Community and Family Data Organized by Risk and Protective Factors, with suggestions for doing so
  b. Ideas and suggestions for creating a partnership with potential program participants and the target community to keep them involved in every step of prevention intervention development and delivery
  c. A brief discussion on identifying community resources
  d. Ways to define the problem using a risk and protective factor approach

At this point, readers would do well to review box 2, "How Can Practitioners Have the Greatest Impact?" presented earlier in this guide. Those observations were presented to provide an overview or sense of the "big picture." Reviewing them at this point will set the framework for the following material.

BOX 6: Using Levels of Evidence To Guide Your Program Planning

The PEPS Expert Panel, as it reviewed the research and practice evidence, used a set of preestablished criteria to rate the relative strength of evidence based on the rigor of the studies and the number of studies with similar findings. These level-of-evidence statements should help practitioners confidently select approaches and specific interventions according to the demonstrated effectiveness of each strategy.

Because prevention activities vary in their emphasis, scope, and content, no two research studies or practice cases are the same. They differ in what they evaluate and the methods used. This can make it difficult to reach a single conclusion about any particular approach. Therefore, several evidence statements may be created to identify and rate the specific conclusions that can be drawn about a prevention approach, as shown by similar findings from more than one study. For instance, studies may show that a prevention approach has strong evidence for attaining a desired effect in the short term but suggestive but insufficient evidence for sustaining that effect over time.

Strong evidence means that given the current state of the art, practitioners can use a prevention approach with the most assurance that the approach can produce the particular effect specified in the evidence statement.

Medium evidence means that although the number of the studies reviewed is limited, there is still substantial support for a prevention approach's ability to produce the particular effect specified in the evidence statement. Practitioners may still use it but should have social, logistic, economic, political, or other reasons to choose this approach.

Suggestive but insufficient evidence means that the prevention approach has shown promise for the particular effect specified but should still be regarded as not well demonstrated. Practitioners should be cautious about undertaking approaches with this level of evidence. However, depending on circumstances, the approach might fit the local situation but would clearly merit further substantial documentation and evaluation of effects. If contradictory results are reported by the studies reviewed, caution should be used in selecting intervention(s) within an approach.

Substantial evidence of ineffectiveness means that the approach has not demonstrated the intended results or has shown negative findings for the particular effect specified. Practitioners should avoid these approaches, as they offer no promise of success at present.

All of the prevention approaches falling within the strong evidence category in this guide should be considered. In certain circumstances, approaches with a strong level of evidence for the particular effect sought by practitioners may not be feasible. Local needs, interests, resources, and abilities - as well as the level of evidence - must all be considered as practitioners make their program development choices.

## Specific Tasks and Activities of Program Development

Table 1, Specific Tasks and Activities of Program Development, lists the four primary steps essential to the development of any prevention program: assessment, planning, delivery, and evaluation. Both the tasks and the activities involved in accomplishing each step are specifically tailored to the challenge of planning and implementing a family-centered prevention intervention.

Table 1: Specific Tasks and Activities of Program Development

Step in Program Development | Tasks | Activities
Step 1: Assessment | Develop a family and community profile of risk and protective factors. | Gather information on demographics and other social indicators.
| | Gather descriptive information (surveys, interviews, meetings).
| | Include formal and informal sources.
| Define the problem. | Compare assessment information with risk and protective factors.
| Choose target family population and prevention approach(es). | Determine where problem has the greatest impact on families.
| Choose target family population and prevention approach(es). | Assess interests, needs, concerns, and issues of families; assess their acceptance of potential approach(es).
| | Assess extent of support and resources from community partners.
| Assess characteristics of target families that will affect their participation. | Understand and respond to family cultures and values.
| Assess characteristics of target families that will affect their participation. | Understand and respond to parental attitudes and beliefs.
| Establish a process for involving families and community partners. | (See above Activities.)
Step 2: Planning | Plan partnerships with parents and community collaborators. | Identify barriers to recruitment of families.
| Plan partnerships with parents and community collaborators. | Identify barriers to participation:; 1. Lack of awareness of benefits.; 2. Cultural barriers.; 3. Support for basic needs.; 4. Negative views of approaches.; 5. Work-site barriers.; 6. Characteristics and settings.
| Address the needs of the targeted children. | Fit intervention to age, gender, and developmental stage of children from participating target families.
Step 3: Delivery | Hire and support staff. | Develop staff hiring criteria (e.g., expertise, training, interpersonal skills).
| | Develop hiring criteria specifically for facilitators and therapists.
| | Train facilitators.
| | Provide staff support (e.g., team building, facilitator meetings).
| Deliver the intervention in a partner relationship with parents. | Involve parents in delivery of the intervention.
| Deliver the intervention in a partner relationship with parents. | Encourage dialog between parents and facilitators.
| | Use parent &quot;graduates&quot; of the program in leadership roles.
| Develop strategies to monitor and retain participants. | Establish and publicize incentives for participation.
| | Monitor participant response and reasons for not participating.
| | Maintain referral network for basic support.
Step 4: Evaluation | Consult with evaluation experts. | Consider options and choose the most appropriate evaluation.
| Involve participants, staff, and other community stakeholders in the evaluation process. | Offer opportunities to participate in the evaluation design.
| Consider a variety of methods and measures to evaluate outcomes. | Choose evaluation methods and measures that accommodate the Activities of the intervention and the budget.
| Identify data sources and develop procedures for collecting data. | Develop unambiguous definitions of what is to be measured and explain to staff.
| Identify data sources and develop procedures for collecting data. | Identify such sources as assessments, client attendance, and feedback.
| Identify data sources and develop procedures for collecting data. | Ensure similar recording of data among different facilitators/therapists.
| Consider cost factors. | Determine scope and design needed to achieve evaluation objectives and outcomes.
| Consider cost factors. | Document significant improvements in outcomes.
| Consider cost factors. | Outline cost of Activities to determine barriers to recruitment and participation.
| Consider cost factors. | Determine length of evaluation.

Table 1 can serve as a checklist for good planning. An expanded treatment of each item is provided in the full guideline.

## Special Planning Issues

### Collecting and Organizing Data by Risk and Protective Factors

To select the most appropriate family-centered approach for a given community, it is vital to identify the specific problems and community needs that increase the risk of adolescent substance abuse as well as the assets or strengths that protect against or reduce these risks. By creating a community profile that organizes data around risk and protective factors, program developers can highlight community and family characteristics that seem to have the greatest correlation with substance abuse. (See table 2, Community and Family Data Organized by Risk and Protective Factors.)

Table 2: Community and Family Data Organized by Risk and Protective Factors

Community and Family Indicators
Social Conditions | Risk Factors (i.e., Problems) | Protective Factors (i.e., Strengths)
Economic Status of Families | Rate of families living in poverty. | Rate of families living in poverty who have successfully raised children to be productive adults.
| | Rate of parents who have achieved economic self-sufficiency.
| | Availability of community programs to assist parents in achieving economic self-sufficiency.
Neighborhood Organization | Violence and crime rates, including rates of juvenile delinquency and homicide among youth. | Number of programs in high-risk communities that work with children and adolescents.
| Rate of suicide among children and adolescents. | Counseling resources available for children and adolescents.
| Rate of suicide among children and adolescents. | Number of neighborhoods that have banded together to make improvements.
| Rate of suicide among children and adolescents. | Availability of child care resources.
| Rate of suicide among children and adolescents. | Presence of housing opportunities for low-income families.
Social Behavior of Children and Adolescents | Rates of children and adolescents with diagnosed conduct and other problem behaviors. | Availability of therapy resources for children and families.
Social Behavior of Children and Adolescents | Violence and crime rates, including juvenile delinquency. | Availability of juvenile court rehabilitation resources.
Social Behavior of Children and Adolescents | Rate of children living in poverty. | Availability of alternative school programs and meaningful vocational education opportunities.
Social Behavior of Children and Adolescents | Rate of unemployment among young adults. | Rate of low-income children enrolled in programs for high achievers, gifted/talented programs.
Family Management and Parenting Practices | Rate of teenaged parents. | Parent and family skills training programs available to all families and to high-risk families.
Family Management and Parenting Practices | Rate of working mothers. | Number of home visitation programs and other resources for new or young parents.
Family Management and Parenting Practices | | Presence of parent self-help groups.
Family Behavior Concerning Substance Abuse | Rate of adult alcohol and drug abusers. | Availability of substance abuse prevention programs for families.
Family Behavior Concerning Substance Abuse | Rate of adolescent substance abusers (alcohol, tobacco, illicit drugs). | Availability of treatment programs for parents and children.
Family Behavior Concerning Substance Abuse | | Community laws and norms regarding adolescents' access to and abuse of substances.
Physical treatment of Children | Rates of child abuse and out-of-home placement. | Availability and adequacy of family preservation programs.
Physical treatment of Children | Rates of child abuse and out-of-home placement. | Percentage of children available for adoption who are adopted.
Physical treatment of Children | Rates of child abuse and out-of-home placement. | Presence of child abuse prevention programs in the community.
Failure to Achieve in School | Rate of school dropouts. | Availability of special education services, tutoring, counseling, etc., for children and adolescents.
Failure to Achieve in School | Rate of students who fail required achievement tests or grades. | Availability of alternative education opportunities.
Failure to Achieve in School | Rate of runaway and homeless youth. | Availability of shelters and services for runaway and homeless youth.
Parental Monitoring | Rate of working mothers. | Availability of afterschool care for children of working parents.
Parental Monitoring | Rate of parents who participate in school events for parents, including conferences. | Flexibility of hours in school and other community programs.
Parental Monitoring | Rate of children in supervised afterschool programs. | Adequacy and safety of public transportation systems for adolescents.
Parental Monitoring | Rate of children who are at home alone after school, by age.
Parental Monitoring | Physical and mental health status of children, including those with developmental delay, learning disabilities, and emotional or behavioral problems.
Family Bonding | | Low-cost opportunities in communities for various family activities.
| | Availability of family support programs for all families and for high-risk families.
NOTE: Wherever possible, information on these indicators should be gathered according to culture and ethnicity as well as geographic or neighborhood distribution.

Members of the target population and community - especially parents, children, and adolescents - should be enlisted to help gather and analyze community and family information. Whatever methods are chosen to gather the data for a community profile, it is essential to involve families who are likely to participate in the family-centered interventions.

Seek the opinions and ideas of a wide variety of people who live in the community. Use telephone interviews, focus groups, written surveys, community meetings, and personal interviews. Include community members of various socioeconomic levels, cultures, languages, and neighborhoods in gathering and analyzing information.

### Establishing a Process for Involving Families and Communities as Partners

The key to success in family-centered approaches is building in, at each stage of development, strategies that involve the participants in planning and decisionmaking. When this is done, the design and implementation of the intervention will be more likely to match the needs, strengths, and expectations of those it serves. In other words, and to reemphasize, involve participants and community leaders in each of these activities:

1. Assessment
  a. Information gathering, problem definition, and target population selection
  b. Analysis of the cultural values and parental attitudes and beliefs that relate to the substance abuse problem and their capacity to affect that problem
2. Planning
  a. Building opportunities for parent participation in planning
  b. Ensuring that practitioners really listen to parents' goals and expectations
  c. Designing programs that reflect the cultures of and diversity in the target families
  d. Designing interventions that integrate the families' natural helping networks
  e. Developing a core of community organizations that collaborate to provide a "safety net" of services to meet the basic needs of participating families
  f. Identifying barriers to recruitment and participation from the community's perspective
  g. Developing strategies to overcome these barriers so that the community is aware of the benefits of the program, feels the program is sensitive to differing cultures, and offers training that will help community members deal more effectively with their family problems
3. Delivery
  a. Serving as support staff and paraprofessional trainers
  b. Helping with logistics and food serving
  c. Serving as language or cultural translators
  d. Encouraging dialogue between parents and facilitators
  e. Using "graduate parents" in leadership roles to motivate others to participate, contact dropouts, and serve as consultants in the replanning and delivery of the intervention
  f. Developing strategies to monitor and retain participants
  g. Establishing and publicizing incentives for participation, such as free transportation and child care, snacks or meals during intervention activities, free coupons for food or video rentals, "graduation" gifts, parties or family outings, access to clothing and food banks, and referral services for legal, medical, housing, and financial aid
  h. Maintaining a referral network for basic family support and monitoring it to identify breakdowns in collaboration and coordination that reduce the family's ability to participate in the intervention
4. Evaluation
  a. Designing a "stakeholders" evaluation specific to the community being served
  b. Working with the project evaluator to hold focus group meetings with potential participants to overcome their reluctance to be involved in programs that include evaluations
  c. Involving participants in the collection of participation rate data for a program to increase their willingness to evaluate it

Program developers, trainers, social workers, and psychologists have conducted conduct assessments and implemented solutions based on what they think is best for the family. With this approach, families rarely have an opportunity to express their ideas about their own needs or to collaborate in the development of a program. It stands to reason that a program designed by "outsiders" will not have the same "fit," participation rate, or effect as one designed with the collaboration and input of the target population. The more involved members of the target community become in the planning and delivery of a program, the more likely they are to use it to their benefit.

### Defining the Problem Using a Risk-and-Protective-Factor Approach

Once the assessment of the community's risk and protective factors is completed, practitioners can work with community partners to analyze the collected information. They will need to identify the most prominent substance abuse problems among children and adolescents in the community and the risk and protective factors that are most clearly associated with those problems.

Substance abuse problems are often hidden or silent. Even statistical data and anecdotal information may not make the problem visible to the community or give a clear outline of its extent. Risk and protective factors can function like clues, pointing out problems that increase the likelihood of substance abuse and factors that help to prevent it. The risk and protective factors outlined earlier are valuable in determining when there is a need to intervene.

Most likely, practitioners will identify several key problems during the assessment. But how can priorities be set so that a plan can be developed? Sometimes the seriousness of the problem and the resources available determine what needs to be done first. One of the most important resources is members of the community who are willing and available to work with practitioners on the problem.

Program developers may want to start with an easy problem to build community support around a successful undertaking. To others, it may seem best to plan a complex, multiproblem strategy that will take full advantage of the resources the community already has in place. Practitioners should know that it is vital to involve community members in identifying the problem so they will develop ownership in the solution.

Community mapping is an important tool for analyzing the scope of community problems:

- In a neighborhood needs map, identify areas with negative community factors, such as unemployment, gangs, and child abuse. Fill in demographic and descriptive information pertaining to these areas.
- In a community assets map, identify community strengths, such as parks, cultural groups, businesses, and religious institutions. Provide demographic and descriptive information pertaining to these areas. Community planners often forget about neighborhood assets and how they can provide support for children and families.

(For more information on community mapping, see the reference guide.)

Defining the problem includes selecting a target population. Questions to ask at this time are:

- Does the problem have its greatest impact on all families in the community or only a certain group of families who are at above-average risk for adolescent substance abuse?
- What was learned during the assessment that might help in selecting the target population? Ask these questions:
  1. Would participation be increased by offering intervention to all families instead of singling out families?
  2. How would high-risk families respond to the availability of extra support?
  3. Which families at risk bring other special strengths and therefore might be more successful?

The more help practitioners have from the community in identifying target families, designing the intervention, providing collateral support services, and funding the intervention, the more likely they are to succeed.

### Identifying Community Resources

Include any and all resources that might support the target families and the community that the prevention approach will serve. Contact such resources and learn how the prevention approach can be coordinated with the support they provide.

In many cases, community resources that support families are outside the obvious formal and traditional sources, such as schools, child welfare agencies, or mainline service organizations with a "substance abuse prevention" or "family" label. Examples include the following:

1. Neighborhood leaders and informal networks
2. Community businesses
3. Neighborhood drop-in programs
4. Community centers
5. Religious organizations, such as churches, temples, and mosques
6. Centers for various cultural groups
7. Child care and Head Start programs
8. Literacy programs

It is also important to identify more formal resources that offer family-centered programs-including parent training, in-home support services, and family therapy. Such resources include, but are not limited to, the following:

1. School-based programs that offer parent training or education about substance abuse prevention
2. Child welfare agencies providing in-home support services to prevent separation of families or specialized foster parent training programs for children with special needs
3. Juvenile court programs that offer parent training or family therapy
4. Universities, community colleges, and hospitals or health clinics that provide special therapeutic services, parent training programs, or special demonstration or research programs

Family therapy interventions should be linked with the social and support services available in the target community. It is not enough to merely identify existing community resources. Practitioners need to establish ways their program can collaborate, coordinate, and perhaps share case management with these other support services. Formal and informal agreements, including memorandums of understanding, case management meetings, and regular multidisciplinary interagency trainings, are helpful. A contract or some other mechanism is necessary to spell out roles and services, such as joint referral, intake, and assessment procedures. Based on these, practitioners need to develop detailed guidance for families on how to best use the other community resources.