# General Recommendations on Family-Centered Approaches

1. Family-centered prevention services are not likely to be successful for families with significant unmet needs related to food, shelter, employment, literacy, and physical and mental health. Prevention practitioners need to either supply the necessary services or help families get them. Basic needs must be met during and after intervention if the prevention program is to be successful.
2. It is unrealistic to expect that a short-term (e.g., 10 to 14 sessions) intervention involving parent training, family skills training, or family therapy will provide a "single-shot cure." This is especially true for children with severe or chronic behavioral problems in difficult family and community contexts. It is more realistic to use repeated "booster" interventions tailored to the major stages of a child's development. It is advisable to consider using other types of interventions before, during, and after or in place of the family-centered intervention. Student counseling, psychiatric interventions, self-help programs, and other educational services help sustain the behavior change process over time.
3. Whenever possible, prevention interventions should be conducted in settings and locations that are comfortable, natural, and easily accessible to parents and children. It is ideal to bring the intervention to the target population, using their schools, workplaces, homes, churches, and community centers.
4. Family-centered approaches are highly compatible with and can be easily integrated into most substance abuse prevention programs. For example, school-based interventions could include a parent and family skills training component or even family therapy interventions. Doing so would strengthen both programs.
5. Family-centered interventions can be made more attractive and accessible by providing vital services that remove barriers to participation, such as transportation, child care, and meals.
6. When community support is sought, family-centered interventions can be more easily integrated into the community. This might involve community outreach to educate relevant community leaders, such as ministers, physicians, and educators, and conducting focus groups and other community education efforts.
7. There is a tremendous need to build and sustain active partnerships between prevention practitioners and researchers. Both groups have skills, knowledge, and expertise to share. Good practice programs are based on the latest research. If advances in knowledge are to be made, researchers need the help of practitioners in designing and implementing studies that capitalize not only on their valuable input, but also on that of local community experts, residents, and parents. Researchers, in turn, continue to seek answers to the many questions that plague the practitioner in designing and implementing prevention programs.
8. Especially when involved in community education, prevention experts should not present themselves as authorities who identify problems in others and then provide the answers "from above." They need to assume the role of information provider and resource expert by:
  a. Providing information on a variety of health and mental health issues
  b. Teaching families to recognize when a problem requires professional attention
  c. Providing information on options and resources in the community
  d. Teaching families how to gain access to resources

Understanding the effectiveness of each prevention approach requires a thorough comprehension of the rating system used. For help in understanding the level-of-evidence statements used to assess the particular effects of each prevention approach, practitioners should refer to box 6.