# Family-Centered Approaches To Prevention of Substance Abuse - What Works

As PEPS evaluated research studies and practice cases, it grouped the evidence into three prevention approaches:

1. Parent and family skills training
2. Family in-home support
3. Family therapy

These approaches focus on the dynamics within the family as a whole and within a community - not merely the individual child within the family. Furthermore, these prevention approaches do not directly address substance abuse among youth. Rather, they address known risk and protective factors that increase or decrease the likelihood that children will begin - or continue - to abuse substances. It is also important to note that many approaches to preventing substance abuse in children and youth, including the three presented in this practitioner's guide, are based on the four developmental models (developmental pathways, social development, social ecology, and contextualism) defined in appendix B, which identify the ways risk and protective factors interact to shape children's lives.

The basic logic for reducing substance abuse is as depicted below:

Family-Centered Prevention Approaches | [image] | Reduce Risk Factors and Increase Protective Factors | [image] | Decrease Likelihood of Substance Abuse Among Youth

Each approach is presented below in terms of its underlying concept, the activities of the studies reviewed, the strength of the evidence supporting the approach, lessons learned from the evidence, and recommendations for practice based on the evidence, as well as the insight of the Expert Panel. General recommendations for practice follow presentation of the three approaches.

## Risk and Protective Factors for Children and Adolescents

Individual Child Factors of Biology, Behaviour, and Personality

Risk Factors | Protective Factors
1. Antisocial and other problem behaviors such as stealing, vandalism, conduct disorder, attention-deficit hyperactivity disorder (ADHA), rebelliousness, and aggressiveness -- particularly in boys; 2. Alienation; 3. High tolerance for deviance and strong need for independence; 4. Psychopathology; 5. Attitudes favorable to drug use; 6. High-risk personality factors such as sensation seeking, low harm avoidance, and poor impulse control | 1. Positive temperament; 2. Social coping skills; 3. Belief in one's own ability to exert control over what happens (self-efficacy) and in one's ability to adapt to changing circumstances; 4. Positive social orientation

Family Factors

Risk Factors | Protective Factors
1. Family behavior concerning substance abuse:; a. Parental substance use and drug use modeling; b. Perceived parental permissiveness of youth's substance use; 2. Siblings' drug use, particularly that of older brothers; 3. Poor family management and parenting practices:; a. Overinvolvement of one parent and distancing by the other; b. Low parental aspirations for children's educational achievement; c. Unclear or unrealistic parental expectations for children's behavior, especially as they relate to the child's developmental level; d. Poor disciplinary techniques, such as lack of or inconsistent discipline and extremely harsh punishment; 4. Poor maternal-child relationships:; a. Lack of maternal involvement in children's activities; b. Cold, unresponsive, underprotective mother; 5. Family conflict (a strong predictor of delinquency and antisocial behavior, including substance abuse); 6. Physical abuse (the earlier the age of experience, the greater its negative effects) | 1. Cohesion, warmth, and attachment of bonding between parents and children during childhood; 2. Parental supervision; 3. Interaction and communication between and among parents, parents and children, and siblings

Environmental Factors

Risk Factors | Protective Factors
1. Peer influence -- rejection or low acceptance, particularly in early school years; 2. Deficient cultural and social norms and laws, such as poor enforcement of minimum purchase age for alcohol and tobacco products, social norms condoning use, and proliferation of tobacco and alcohol product advertisements; 3. Extreme poverty, for children with behavior problems and other risk factors; 4. Neighborhood disorganization that reduces the sense of community, increases experiences with crime, and creates high mobility and transience; 5. Failure to achieve in school, especially in the late elementary grades, regardless of whether it is due to behavior problems, truancy learning disabilities, poor school environment, or other causes | 1. Sources of positive emotional support outside the family, such as close friends (one or several), neighbors, extended family, peers, and elders; 2. Formal and informal supports and resources available to the family; 3. Community and school norms, beliefs, and behavioral standards against substance abuse; 4. Successful school performance and strong commitment to school

Box 2 lists principles practitioners should follow in addressing the risk and protective factors on which the following prevention approaches are based.

BOX 2: How Can Practitioners Have the Greatest Impact?

In addressing the various risk and protective factors around which family-centered approaches are built, practitioners should keep in mind the following principles:

1. Select prevention approaches according to the risk level of the targeted families. Differentiate among:
  a. Families not yet known to have any risk factors,
  b. Families with children who belong to subgroups that have risk factors for substance abuse but do not yet use substances, and
  c. Families with children who already are known to have such risk factors as antisocial behavior and conduct disorder.
2. Respectively, risk levels a, b, and c represent the population groups to which three categories of prevention activities (universal, selective, or indicated) should be directed (Gordon 1983, 1987; Institute of Medicine 1994).
3. Focus on families with young, school-aged children (before negative behaviors and family problems become entrenched).
4. Reduce exposure to risks.
5. Enhance protective factors.
6. Choose strategies that are developmentally and gender appropriate.
7. Develop interventions in multiple contexts and settings (e.g., schools, cultural life, religious institutions, neighborhoods, and communities).
8. Address multiple risk factors simultaneously (e.g., working to reduce domestic conflict and children's antisocial behavior while improving parenting skills and school performance).
9. Build on families' strengths, preserve their integrity (including their language and culture), and encourage their leadership in the growth process.

## Prevention Approach 1: Parent and Family Skills Training

Family functioning, structure, and values have a significant impact on children's capacity to develop prosocial skills and cope with life's challenges. Parent and family skills training can provide parents and family members with new skills. These skills enable families to better nurture and protect their children, help children develop prosocial behaviors, and train families to deal with particularly challenging children.

This prevention approach addresses two clusters based on the risk levels of the target populations:

1. Families with children who are not known to have risk factors and families with children who are exposed to risk factors and are therefore at above-average risk. Common risks might include being in a single-parent family, a family in economic distress, or a family of divorce.
2. Families with children who are at high risk because they are exposed to multiple risk factors or have a high level of exposure to a single risk factor. Examples might be children identified as having serious behavior problems, as being delinquent, as having substance-abusing parents, or as being victims of child abuse.

The risks faced by families in the first cluster call for universal or selective prevention measures, as defined in the Institute of Medicine's (IOM's) classification system. Indicated prevention measures are appropriate for the second cluster (Gordon 1983, 1987; Institute of Medicine 1994).

Because the activities and levels of evidence are unique to each cluster, they are presented separately below. The lessons learned and recommendations for practice that follow apply to both clusters.

### Expected Changes and Key Activities for Approach 1

Cluster 1. This cluster, as noted above, includes families with children who have no known risk factors. As noted earlier, according to the IOM's classification system, universal preventive measures are appropriate for these families. Cluster 1 also includes families with children who are exposed to risk factors and are therefore at above-average risk. Selective preventive measures are appropriate for these families.

The parent and family training activities or interventions in this cluster include some training sessions that involve the child and other family members and others that are parent oriented. All of the activities focus on changes in:

1. Parents - Acquiring or improving parenting skills, child management abilities, psychological helping skills, relationship development, and empathy
2. Families - Improving family cohesion, organization, relationships, and conflict resolution
3. Youth - Improving general child behavior, psychological adjustments, attachment to family, and commitment to school

Activities include:

1. Didactic presentations, both live and videotaped, followed by discussions
2. Role-playing and skills practice sessions
3. Curriculum-based training to recognize and modify risk and protective factors
4. Modeling sessions on interaction, communication, and crisis handling
5. Cognitive-behavioral workshops and multisession training programs

(See box 3 for the levels of evidence for this cluster.)

BOX 3: Levels of Evidence - Approach 1

Cluster 1 For families with children who are not known to have risk factors and for families with children who are exposed to risk factors, the research and practice evidence reviewed indicates that it is possible to implement parent and family skills training interventions:

- There is strong evidence that these interventions can stabilize or improve the conditions that decrease risk factors for substance abuse, such as poor parent-child communication, child problem behavior, inadequate parenting skills, poor family relationships, parental substance use, family conflict, and family disorganization.
- There is suggestive but insufficient evidence that, when specifically directed, these interventions can improve children's social skills and prosocial behavior.
- There is suggestive but insufficient evidence that, when specifically directed, these interventions can reduce parental stress and depression, improve children's self-esteem, and promote improvements related to differences in social assimilation between parents and children.
- There is suggestive but insufficient evidence that using a combination of parent training, children's social skills training, and family relationship training leads to greater improvements overall in parent-child relationships than would any of these interventions alone.

Cluster 2 For families with children who are at high risk for substance abuse because they either are exposed to multiple risk factors or have a high-level exposure to a single risk factor, such as conduct disorder, the research and practice evidence indicates that it is possible to implement parent and family skills training interventions:

- There is strong evidence that these interventions can decrease risk factors such as child problem behavior and poor parenting skills and increase protective factors such as healthy family communication, bonding, and conflict resolution.
- There is suggestive but insufficient evidence that these interventions reduce parents' stress, depression, and substance use; improve children's self-esteem; and promote improvements related to differences in social assimilation between parents and children.
- There is strong evidence that these interventions have a positive and lasting effect in improving parenting skills and behaviors as well as reducing diagnosed problem behaviors in children.

NOTE: The criteria used to rate the strength of evidence for each prevention approach are shown in appendix A.

Cluster 2. As noted above, this cluster includes families with children at high risk for substance abuse because they are exposed to multiple risks or have a high level of exposure to a single factor, such as conduct disorder. Indicated preventive measures are appropriate for these families (Institute of Medicine 1994).

The parent and family training activities or interventions examined in this cluster include parent training without child involvement, parent training with separate child training, family skills training, and parent training plus family skills training.

All of the activities focus on changes in:

1. Parents - Improving parents' attitudes toward their children, aquiring or improving parenting skills, child management abilities, problem-solving skills, communication skills, and crisis management abilities
2. Youth - Improving general behavior, acquiring or improving self-control and compliance, reducing antisocial and other problem behaviors, and reducing arrest rates

Activities include:

1. Videotaped modeling sessions, with and without counseling and practice
2. Manual-based training, with and without discussions
3. Didactic, role-playing, and skill practice sessions
4. Cognitive-behavioral and problem-solving skills training
5. Behavioral parent training
6. Parent and teacher training
7. Structural family therapy and family effectiveness training
8. Parent counseling
9. Individual and group therapy for parents, both with and without children

(See box 3 for the levels of evidence for this cluster.)

### Lessons Learned for Approach 1

1. Research demonstrates that parent and family skills training can greatly benefit parents, the family, and children:
  a. Parents increased their knowledge, parenting skills, problem-solving skills, child management skills, and coping skills and improved their attitudes, including acceptance of their children.
  b. Parent-child relations showed increased family cohesion and decreased family problem behaviors, family conflicts, and substance abuse.
  c. Children showed increased prosocial behaviors and decreased hyperactivity, social withdrawal, aggression, and delinquency.
2. Research suggests that increased parental effectiveness is associated with their decreased use of substances. The causal direction of this relationship, however, is unknown:
  a. Some positive effects may be due to children's exerting pressure on parents to stop substance use.
  b. It is also likely that some changes are due to improved communication skills and an increased parental awareness of the effects of their drug use on family dynamics.
3. Research suggests that parent and family training may have an impact on parents being treated for substance abuse that is above and beyond the treatment effect:
  a. This may be particularly true for women who increase their ability to communicate and manage their families effectively.
  b. Adding parent and family training to addiction treatment may also reduce the likelihood of relapse.
4. Research suggests that the more competent the trainer (e.g., having good group process skills) and the better he or she is able to relate to parents and family members, the more likely it is that parents will enter the programs and master higher functioning skills.
5. Research suggests that videotaped training and modeling, when combined with group discussion and a therapist's consultation, can be an effective and economical way to teach new behaviors and skills.

### Recommendations for Practice for Approach 1

The PEPS Expert Panel also made recommendations regarding parent and family skills training based on members' experience and their interpretation of the research and practice evidence. The panel's recommendations focused on the benefits of combining parent training and children's skills training with family therapy, cultural content, environmental context, multicomponent programs, and efforts to retain participants:

1. Combining parent training and children's skills training with family therapy addresses a broader array of family risk and protective factors for substance abuse and helps prevent "family sabotage effects" that emerge when only the individual child or parent is treated.
2. Parent and family skills training is easier to implement than family skills therapy because it is highly structured and requires fewer skills. It is also easier to adapt to meet ethnic, cultural, regional, and child developmental stages.
3. Parent and family skills training programs should incorporate cultural content. Specifically, culture can serve as the core around which changes in family dynamics and roles can be initiated through parent and family skills training interventions. Training programs should identify, build on, and measure the intervention's ability to maximize the family's cultural strengths.
4. When parents do not succeed in parent and family skills training, it is important to consider more than the training class itself. Other serious problems in the family and environment might be affecting the parents' ability to learn. Consider factors such as home violence, unsafe neighborhood, and poverty-related stresses.
5. For greater success, address multiple family and community contexts, such as reducing social isolation, building peer support networks, increasing awareness of community resources, and coping with depression and parenting stress. When possible, use an integrated family-school strategy.
6. Research demonstrates that parents of children with conduct problems, even those with multiple problems, are often successfully retained in parent training. This is in contrast to an opinion frequently expressed by prevention specialists that such retention is nearly impossible. It may be that parent training promotes participant retention because parents view it as a helpful and acceptable form of intervention, or it may be that it increases the parents' hope and sense of competence.
7. Parent training interventions for children with conduct problems are more effective with younger children than with older children. Prevention programs should incorporate the concept that early intervention is best.

(General recommendations are listed on pages 20-22 immediately following the presentation of approaches.)

## Prevention Approach 2: Family In-Home Support

This prevention approach targets families who are at high risk because they face multiple risk factors or have a high level of exposure to one risk factor. According to the Institute of Medicine's framework, indicated preventive measures are appropriate for these families.

These families are more likely than others to fall apart and have children placed outside the home. In-home support addresses these risks simultaneously and tailors its interventions to the family's unique situation. Intensive and comprehensive services provided for several months to a year can help stabilize the family and enhance the parents' ability to nurture and protect their children. Among the most common goals of family in-home support is decreasing the likelihood of domestic violence, child abuse, or neglect and preventing placement of children in foster homes or institutions for juvenile delinquents (Kinney et al. 1990).

### Expected Changes and Key Activities for Approach 2

The primary objective of in-home prevention interventions is to preserve families so they can nurture, protect, and teach their children to become capable, competent, and caring adults. All activities focus on changes in:

1. Parents - Acquiring or improving parenting skills related to discipline, family relations, communication, and anger management and for decreasing the likelihood of child abuse and/or neglect
2. Youth - Training in communication skills and anger management, increasing compliance with curfew and school attendance, and diminishing the rates of arrests and criminal activities among juvenile offenders
3. Families - Preventing children from being removed from the family, and reuniting previously removed children with their families

Activities include:

1. Direct services - Transportation, cash assistance, clothing, food, help with home repairs, etc.
2. Social services - Individual and family counseling, crisis intervention, behavior management training, substance abuse referrals for treatment, case management services, and reuniting children with their families after outside placement

BOX 4: Levels of Evidence - Approach 2

The research evidence reviewed concentrates on in-home support services as indicated preventive measures - comprehensive, intensive, multipurpose services provided in the home and designed to address a range of family problems, typically involving all family members.

The research and practice evidence reviewed indicates that it is possible to implement in-home support services as indicated preventive measures

- There is medium evidence that multisystemic therapy, provided in the home, is effective in reducing juvenile criminal activity and rearrest.
- There is medium evidence that multisystemic therapy, provided in the home, is effective in improving family characteristics associated with juvenile antisocial behavior, such as family cohesion and symptomatology.
- There is medium evidence that home-based family preservation services are
- effective in avoiding out-of-home placement and reducing the number of days of placement.

NOTE: The criteria used to rate the strength of evidence for each prevention approach are shown in appendix A.

### Lessons Learned for Approach 2

1. The level of evidence is not strong. Practitioners need to be aware that although use of the in-home support services prevention approach is currently in favor, there is a dearth of controlled studies. One reason is the ethical issue of assigning families with identified needs and problems to a nontreatment control group.
2. The use of comparison treatment conditions as a control group is underutilized.
3. Only very broad conclusions can be reached regarding the provision of services and the effect of an intervention on families. This is due to a number of reasons, among them the scarcity of experimental studies having a common focus and the difficulty of designing research that:
  a. Teases out the differing effects of particular elements, such as different facets of an intervention
  b. Examines whether there is a priority of needs
  c. Measures the interrelationships of specific elements of the intervention and specific outcomes

### Recommendations for Practice for Approach 2

The PEPS Expert Panel's recommendations for in-home support services were based on members' experience and interpretation of the research findings. The panel focused on family-centered assessments, strength-based assessments, fragmentation of services, use of neighborhood-based family workers, and a variety of family preservation efforts:

1. Families should be encouraged to become partners in any assessment of family needs in the community. Assessments should include the family's perspectives on both the nature of the problems and the ways those problems should be solved. Assessments should reflect the family's perceptions of its needs, problems, goals, objectives, and timelines. Including the family in this process is in itself an intervention that increases its ability to manage and make decisions.
2. Include family contexts and informal supports, such as involvement of members of the extended family and churches, in assessments and services plans.
3. Experience suggests that assessments and services plans are more useful when they focus not only on problems but also on the strengths, competencies, and capabilities that help the family survive. When a family's strengths are enhanced and weaknesses reduced, its capacity to thrive grows. The evaluation of family strengths should include the family's readiness to change and the parents' ability to invest in learning parenting skills.
4. Families in crisis may need numerous health and social services at times when they are least able to find and gain access to them. Often the services they need are fragmented and compartmentalized. Families must work with several provider representatives and fill out duplicative agency-specific paperwork. During crisis, families need integrated and comprehensive resources. Any effort to simplify the process should have a significant impact on the ability of families in crisis to obtain the help they need.
5. Neighborhood-based family workers should be recruited to form a bridge between agencies and families. Such workers help both families and agencies integrate and manage the services received. They help care providers form alliances with formal and informal support networks in the community that can in turn strengthen family functioning. Such workers also provide ongoing emotional support and a consistent flow of accurate information.

(General recommendations are listed immediately following the presentation of approaches.)

## Prevention Approach 3: Family Therapy

Like the second prevention approach, "in-home services," this prevention approach targets families at high risk because they face multiple risk factors or have a high level of exposure to a particular risk factor. The interventions in this approach are designed to improve family functioning and reduce juvenile delinquency, recidivism, child abuse, and other strong antisocial behaviors.

Family therapy helps family members develop interpersonal skills and improve communication, family dynamics, and interpersonal behavior. It can be used to help family members improve their perceptions about one another, decrease negative behavior, and create skills for healthy family interaction. It can also be used to enhance parenting skills and reduce inappropriate parental control over children.

### Expected Changes and Key Activities for Approach 3

The expected changes in this prevention approach all focus on improving family functioning and reducing children's recidivism and other problem behaviors.

All activities focus on changes in:

1. Families - Increasing mutual positive reinforcement and decreasing maladaptive interaction patterns; improving family dynamics in families with juvenile offenders or adolescents with strong antisocial behaviors; acquiring skills, improving communication, learning effective discipline methods, and learning self-management skills
2. Youth - Reducing behavioral and emotional problems and repeat offender rates, improving the functioning of juvenile offenders, and preventing the initiation of substance abuse

Activities include various types of family-centered therapies used with diverse groups of clients. The following illustrate some of the therapies and groups treated:

1. Functional family therapy, used by paraprofessional therapists and foster care caseworkers for families with seriously delinquent youth (Alexander and Parsons 1982)
2. Structural family therapy, used for Hispanic families with boys diagnosed as having opposition disorder, conduct disorder, adjustment disorder, or anxiety disorder (Santisteban et al. 1995)
3. Multisystemic family-ecological therapy for families with juvenile offenders (Henggeler et al. 1986; Henggeler, Melton, and Smith 1992)

(See box 5 for levels of evidence for this approach.)

BOX 5: Levels of Evidence - Approach 3

The research and practice evidence reviewed indicates that it is possible to implement family therapy for families with children who are at high risk of substance abuse:

- There is medium evidence that family therapy results in enhanced parenting skills, improved family communication, increased parental knowledge about how to reduce antisocial child behavior, improved perceptions and attitudes of parents and adolescents about each other, and reduced inappropriate control of parents over adolescents.
- There is strong evidence that family therapy reduces recidivism in delinquent teenagers.

NOTE: The criteria used to rate the strength of evidence for each prevention approach are shown in appendix A.

### Lessons Learned for Approach 3

1. Research demonstrates that family therapy is an effective resource for improving family functioning, increasing parenting skills, and decreasing the recidivism of juvenile offenders.
2. Most empirical investigations of family therapy have focused on families with adolescents, many of whom are juvenile offenders. These youth are often much more difficult to influence and have moderate to severe disorders. The impact of family therapy in families with younger children and less severe behavior problems needs to be thoroughly investigated.
3. Research and practice demonstrate that family therapy can be part of a multicomponent prevention effort. For instance, family therapy can be a component in prevention efforts that include in-home family support and school-based problem-solving counseling.

### Recommendations for Practice for Approach 3

The PEPS Expert Panel members made recommendations regarding family therapy based on their experience and their interpretation of the research and practice evidence. The panel focused on interagency collaboration, participant recruitment and retention, cultural context, and interventions appropriate to the developmental level of young children:

1. Because families in crisis are likely to receive services from multiple agencies, family therapy providers should be linked with social and other services agencies. Interagency collaboration and coordination and integrated case management are essential. Formal and informal agreements, including memorandums of understanding, case management meetings, and regular multidisciplinary interagency trainings, are helpful. A special contract or some other mechanism is necessary to spell out roles and services such as joint referral, intake, and assessment procedures.
2. Family therapy is still viewed very negatively among people from some regions of the country and among certain ethnic and socioeconomic groups. This makes recruitment and retention in family therapy difficult. The intervention design needs to address educating the target population to increase their positive regard for family therapy. Neighborhood volunteers and community outreach workers can be trained to give lectures on depression, anxiety, substance abuse, and child problem behaviors to help demystify family therapy. These activities, offered in collaboration with churches, schools, and community centers, can serve as a way to recruit families into therapy.
3. Practitioners should understand the cultural values, beliefs, and traditions of the families they serve. They should also be familiar with the resources available in the community where the family lives.
4. Family therapy that requires a participant's understanding of complex family and interpersonal dynamics may not be appropriate for young children. When children are to be participants, interventions should be chosen that are appropriate to their developmental level (e.g., family play therapy for families with young children).