# What Puts Children And Adolescents At Risk For Substance Abuse?

Researchers believe that to maximize the prevention of adolescent substance abuse, it is important both to reduce risks and to enhance protective factors.

Certain conditions - risk and protective factors - in the lives of some children and adolescents make it more or less likely that they will use alcohol, tobacco, or illicit drugs. Interaction of risk and protective factors within and among the three domains discussed below can affect the likelihood of adolescent substance abuse. For example, a recent study concluded that, despite similar exposures to violence in their neighborhoods, children showed varying degrees of successful adaptation and behavioral problems. The impact of the risk factors in the community was lessened by the protective factors of family warmth, cohesion, and strong parenting (Richters and Martinez 1993). Similarly, high population density, overcrowding, and poor housing appear to contribute to antisocial behavior and delinquency - which, in turn, are known risk factors for substance abuse.

In general, risk and protective factors can be seen as operating in three areas of influence, or domains:

1. Individual child factors of biology, behavior, and personality
2. Family factors
3. Environmental factors

Risk and protective factors within each domain are listed below. While there are fewer identified protective factors than risk factors, their interaction with risk factors means that practitioners should always try to enhance them as they strive to reduce risk factors. However, doing so can be challenging because risk and protective factors are complex. In addition to the difficulties that may be posed by their number, intensity, and duration, risk and protective factors work within a dynamic and interactive system.