# How Big A Problem Is Substance Abuse Among Youth?

What do we know about our kids and substance abuse? Data on substance abuse among young children have not been systematically collected. However, the Monitoring the Future Study (University of Michigan Institute for Social Research 1997) shows that the use of illicit drugs by adolescents increased significantly between 1991 and 1996, representing a reversal of previous downward trends. By 1997, the resurgence showed signs of leveling off, especially among eighth-grade students.

## Eighth-Grade Students

The percentage of eighth-grade students reporting any marijuana use in the past month increased from 3 percent in 1991 to 10 percent in 1997, down from 11 percent in 1996. The percentage reporting any cigarette use in the past month rose from 14 percent in 1991 to 19 percent in 1997, down from 21 percent in 1996. The percentage reporting any heroin use within the past month, although quite low, more than doubled from 0.3 percent in 1991 to 0.7 percent in 1996 before easing to 0.6 percent in 1997. Similarly, the percentage reporting any hallucinogen use rose from 0.8 percent in 1991 to 1.8 percent in 1997, also slightly lower than the year before. (University of Michigan Institute for Social Research 1997).

Box 1 illustrates the substance use experience of eighth-grade students as noted in the 1997 Monitoring the Future Study. All of these figures are slightly lower than the 1996 results.

BOX 1: Lifetime Substance Use by Eighth-Grade Students in 1997

In 1997, the percentages of eighth-grade students reporting the use of a substance of abuse at least once in their lifetime were reported as follows:

1. Alcohol - 54 percent
2. Cigarettes - 47 percent
3. Marijuana - 23 percent
4. Inhalants - 21 percent
5. Smokeless tobacco - 17 percent
6. Stimulants - 12 percent
7. Hallucinogens - 5 percent
8. Cocaine - 4 percent
9. Heroin - 2 percent

(University of Michigan Institute for Social Research 1997)

## Tenth-Grade Students

Of students in the tenth grade, the percentage reporting any marijuana use in the past month increased from 8 percent in 1992 to 21 percent in 1997. The percentage reporting any cigarette use in the past month rose from 21 percent in 1991 to 30 percent in 1997. The percentage reporting any heroin use within the past month is quite small but tripled from 0.2 percent in 1991 to 0.6 percent in 1997. Similarly, the percentage reporting any hallucinogen use doubled from 1.6 percent in 1991 to 3.3 percent in 1997 (University of Michigan Institute for Social Research 1997).

## High School Seniors

The percentage of high school seniors reporting any illicit drug use in the past month was nearly 40 percent in 1979; it decreased to a low of 14 percent in 1992 but increased to 26 percent in 1997. Perhaps the most troubling increase involved marijuana. The percentage of high school seniors reporting marijuana use in the past month was 37 percent in 1979; it dropped to 12 percent in 1992 but rose to 24 percent in 1997. Similarly, the past-month use of cigarettes declined from a high of 38 percent in 1977 to a low of 28 percent in 1992. However, by 1997, the rate had increased to 37 percent (National Institute on Drug Abuse 1997; University of Michigan Institute for Social Research 1997).

High school seniors' reports of using a hallucinogen during the past month have fluctuated between 2 percent and 4 percent from 1975 through 1997. However, their rate of lifetime use of hallucinogens has risen from about 10 percent during the early 1990s to 15 percent in 1997, signaling an increase in experimentation (University of Michigan Institute for Social Research 1997).

The use of heroin by high school seniors has always been low, generally about 0.2 to 0.3 percent from the late 1970s through the early 1990s. However, though still less than 1 percent, the rate increased somewhat to 0.5 percent in 1997 (University of Michigan Institute for Social Research 1997).

## Alcohol Use Remains High

In general, alcohol use among high school students has remained fairly stable in the past several years, although the rates are unacceptably high. Slightly more than half of high school seniors report drinking in the past month, a fairly consistent pattern in the 1990s. This rate is down from about 70 percent in the late 1970s and early 1980s. Even among eighth-grade students, more than half have tried alcohol, and a quarter report having had alcohol within the past month (University of Michigan Institute for Social Research 1997).