# Why Use Family-Centered Approaches? Aren't Our School and Community Efforts Sufficient?

Most Americans agree that the family is primarily responsible for ensuring the safety of children and for providing the nurturing and guidance children need. Skillful parenting helps children to become competent, caring adults who can live together peacefully and productively. In the past few decades, however, dramatic changes have taken place in American society and in the character of American family life (especially the role of women). Many of these changes can stress the family's ability to nurture healthy children and increase the likelihood that our youth, even at a very early age, will turn to substance abuse. Just listing some of these stress factors makes the challenge obvious:

1. Economic deprivation - For many economically deprived youth, drug trafficking and substance abuse have become the only perceived options for breaking the cycle of poverty and getting the goods and advantages their parents cannot afford to give them (Hawkins, Catalano, and Miller 1992).
2. Homelessness - Drug use by homeless and runaway youth in shelters was reported in one study in the southeastern United States to be two to seven times higher than in comparison school samples (Fors and Rojek 1991).
3. Mothers in the workforce - Working mothers have less time than nonworking mothers to spend with and monitor their children. Less maternal involvement is associated with an increased risk for behavior problems, conduct disorders, and substance abuse as the child approaches adolescence (Kandel and Andrews 1987).
4. Single-parent families - Children living in single-parent families are more likely than others to have emotional problems and academic difficulties, which in turn are risk factors for substance abuse (Emery 1988; McLanahan 1988; McLanahan and Sandefur 1994).
5. Child abuse and neglect - About 90 percent of the perpetrators of child maltreatment are parents and other relatives of the victims. In recent years, substance abuse by parents has come to be seen as a major cause of child abuse and neglect (National Center on Child Abuse and Neglect 1994).
6. Teenaged mothers - Teenaged mothers, many of whom lack adequate social support, are less capable than adult mothers of parenting and managing crises and may be more likely to turn to substance abuse to cope with stress (Department of Health and Human Services 1993).

The case for family-centered approaches is strong. While school- and community-based substance abuse prevention programs are essential, they are not sufficient. Frequently, schools do not begin addressing the substance abuse problem until adolescence, although the data indicate that the problem often begins in preadolescence. If families are to be successful in preventing substance abuse during the early years of a child's development, both parents and children need to develop the behaviors and skills that will enable them to manage themselves and their families in ways that support healthy growth. This training and support is all the more important today as a variety of stressors push and pull the family from every side.

Some families require only occasional support as specific problems arise. Others have greater difficulty and need ongoing support, and a small percentage of families who have a great need for resources and support have only a marginal capacity to find and use them. These families may need active assistance to protect the children and to help the parents impart the values and skills that will enable their children to succeed as adults.