# Resource Guide

This Resource Guide provides suggestions for family-centered resources. The first section lists names and addresses of researchers and practitioners whose work was considered as evidence in evaluating the various intervention programs. Names and addresses reflect information that was current at the time these individuals were last involved with PEPS. Because detailed descriptions of their program planning and content are beyond the scope of this guideline (and often are not fully described in their published works), CSAP thought that those interested in implementing specific strategies might want to obtain more detailed information directly from these researchers and practitioners. The second section of this appendix lists the various Federal Government agencies and nongovernment organizations that provide information, resources, and guidance regarding family-related interventions and programs. Some of these organizations have information clearinghouses. It also lists examples of foundations that provide support for family-centered interventions or research. Some of the foundations also provide educational materials for practitioners or the lay public.

## Researchers and Practitioners

### Researchers

- Georgia Aktan, Ph.D.
- Needs Assessment Studies
- Michigan Department of Public Health
- Center for Substance Abuse Services
- 3423 Martin Luther King, Jr. Boulevard
- P.O. Box 30195
- Lansing, MI 48909

- James Alexander, Ph.D.
- Department of Psychology
- University of Utah
- Salt Lake City, UT 84112

- Arthur Anastopoulos, Ph.D.
- Department of Psychiatry
- University of Massachusetts Medical Center
- 55 Lake Avenue North
- Worcester, MA 01655

- Lew Bank, Ph.D.
- Oregon Social Learning Center
- 207 East Fifth Avenue, Suite 202
- Eugene, OR 97401

- Cole Barton, Ph.D.
- Psychology Department
- Davidson College
- Davidson, NC 28036

- Martha Bernal, Ph.D.
- Department of Psychology
- Arizona State University
- Box 871104
- Tempe, AZ 85287-1104

- Marianne Berry, Ph.D.
- School of Social Work
- University of Texas at Arlington
- Arlington, TX 76019

- Charles Borduin, Ph.D.
- Department of Psychology
- University of Missouri, Columbia
- 21 McAlester Hall
- Columbia, MO 65211

- Richard Catalano, Ph.D.
- Social Development Research Group
- School of Social Work
- University of Washington
- 146 North Canal Street
- Suite 211, XD-50
- Seattle, WA 98103

- Thomas Dishion, Ph.D.
- Oregon Social Learning Center
- 207 East Fifth Avenue, Suite 202
- Eugene, OR 97401

- Robert Felner, Ph.D.
- National Center on Public Education and Social Policy
- University of Rhode Island
- Shephard Building, Room 300
- 80 Washington Street
- Providence, RI 02903

- Matthew Fleischman, Ph.D.
- Family Research Associates
- 81 East 14th Street
- Eugene, OR 97401

- Rex Forehand, Ph.D.
- Institute for Behavioral Research
- Psychology Department
- Barrow Hall, Room 111
- University of Georgia
- Athens, GA 30602

- Donald Gordon, Ph.D.
- Department of Psychology
- Ohio University
- Athens, OH 45701-2979

- Louise Guerney, Ph.D.
- Individual and Family Consultation Center
- The Pennsylvania State University
- University Park, PA 16802

- David Hawkins, Ph.D.
- Social Development Research Group
- School of Social Work
- University of Washington
- 146 North Canal Street
- Suite 211, SC-50
- Seattle, WA 98195

- Scott Henggeler, Ph.D.
- Department of Psychiatry and Behavioral Sciences
- Medical University of South Carolina
- 171 Ashley Avenue
- Charleston, SC 29425

- Nicholas Ialongo, Ph.D.
- School of Hygiene and Public Health
- Department of Mental Hygiene
- Johns Hopkins University
- 624 North Broadway
- Baltimore, MD 21205

- Alan Kazdin, Ph.D.
- Department of Psychology
- Yale University
- P.O. Box 11A
- Yale Station
- New Haven, CT 06520-7447

- Michael Klein, Ph.D.
- Department of Educational Psychology
- University of Wisconsin_Milwaukee
- P.O. Box 413
- Milwaukee, WI 53201

- Patricia Knapp, Ph.D.
- Department of Psychology
- University of Maryland Baltimore County
- 1000 Hilltop Circle
- Baltimore, MD 21250

- Rick Kosterman, Ph.D.
- Social Development Research Group
- School of Social Work
- University of Washington
- 9725 3rd Avenue, N.E., Suite 401
- Seattle, WA 98115

- Karol Kumpfer, Ph.D.
- Department of Health Education
- HPER N-215 (Annex 2007)
- University of Utah
- Salt Lake City, UT 84112

- Patricia Long, Ph.D.
- Department of Psychology
- Oklahoma State University
- 215 North Murray
- Stillwater, OK 74078

- Barton Mann, Ph.D.
- Department of Psychology
- University of Missouri_Columbia
- 210 McAlester
- Columbia, MI 65211

- Hector Myers, Ph.D.
- Center for the Improvement of Child Caring
- 11331 Ventura Boulevard, Suite 103
- Studio City, CA 91604

- Gerald Patterson, Ph.D.
- Oregon Social Learning Center
- 207 East Fifth Avenue, Suite 202
- Eugene, OR 97401

- John Reid, Ph.D.
- Oregon Social Learning Center
- 207 East Fifth Avenue, Suite 202
- Eugene, OR 97401

- Daniel Santisteban, Ph.D.
- Center for Family Studies
- Department of Psychiatry and Behavioral Sciences
- University of Miami School of Medicine
- 1425 NW 10th Avenue
- Miami, FL 33136

- Richard Spoth, Ph.D.
- Social and Behavioral Research Center for Rural Health
- Center for Family Research in Rural Mental Health
- Iowa State University
- ISU Research Park
- Building 2, Suite 500
- 2625 North Loop Drive
- Ames, IA 50010

- Fred Springer, Ph.D.
- EMT Associates, Inc.
- 771 Oak Avenue Parkway, Suite 2
- Folsom, CA 95630

- José Szapocznik, Ph.D.
- Department of Psychiatry
- University of Miami School of Medicine
- University of Miami
- 1425 NW 10th Avenue
- Miami, FL 33136

- Ronald Thompson, Ph.D.
- Program Planning, Research, and Evaluation
- Common Sense Parenting Program
- Father Flanagan's Boys Home
- Boys Town, NE 68010

- Richard Tremblay, Ph.D.
- Research Unit on Children's PsychoSocial Maladjustment
- University of Montréal
- 750 Gouin Boulevard East
- Montréal, Québec, Canada H2C 1A6

- Robert Wahler, Ph.D.
- Department of Psychology
- 227 Austin Peay Building
- University of Tennessee
- Knoxville, TN 37996

- Elaine Walton, Ph.D.
- College of Social Work
- Ohio State University
- 1947 College Road
- Columbus, OH 43210

- Carolyn Webster-Stratton, Ph.D.
- Parenting Clinic
- School of Nursing
- Box 354801
- 1107 N.E. 45th Street, Suite 305
- University of Washington
- Seattle, WA 98105-4631

- Peter Wilson, Ph.D.
- Department of Psychology
- University of Sydney
- Sydney, N.S.W. 2006, Australia

- Sharlene Wolchik, Ph.D.
- Department of Psychology
- Arizona State University
- P.O. Box 871104
- Tempe, AZ 85287-1108

### Practitioners

- Stephen Bavolek, Ph.D.
- The Nurturing Program for Parents and Children
- Family Development Resources
- 27 Dunnwoody Court
- Arden, NC 28704-9588

- Bernell Boswell
- Families in Focus Program
- The Cottage Program International
- 57 West South Temple, Suite 420
- Salt Lake City, UT 84101-1511

- Herbert Callison
- Kansas Family Initiative
- Kansas Department of Social and Rehabilitation Services
- P.O. Box 47054
- Topeka, KS 66647

- Eileen Carroll
- In-Home Care
- California Department of Social Services
- Office of Child Abuse Prevention
- 744 P Street, Mail Slot 19-82
- Sacramento, CA 95814

- Mary Heckenliable
- Intensive Family Preservation Program
- Hall Neighborhood House, Inc.
- 361 Bird Street
- Bridgeport, CT 06605

- Pat Mouton, M.S.W.
- Parenting for Prevention Program
- King County Division of Alcohol and Substance Abuse Services
- 999 3rd Avenue, Suite 900
- Seattle, WA 98104

- Ted Strader
- Creating Lasting Connections
- Council on Prevention and Education: Substances
- 1228 East Breckenridge Street
- Louisville, KY 40204

- Linda Wheeler
- Families and Schools Together Program
- Family Service America
- 11700 West Lake Park Drive
- Milwaukee, WI 53224-3099

## Agencies, Organizations, and Foundations

### Government Agencies

#### Administration for Children and Families

- Administration on Children, Youth, and Families330 C Street, S.W., Room 2026 Washington, DC 20201 (202) 205-8347 Internet: http://www.acf.dhhs.gov

- Children's Bureau330 C Street, S.W., Room 2070 Washington, DC 20201 (202) 205-8618

- Child Care Bureau200 Independence Avenue, S.W. Room 320F Washington, DC 20201 (202) 401-6947

- Child Welfare Bureau330 C Street, S.W., Room 2068 Washington, DC 20201 (202) 205-8618

- Family and Youth Services Bureau330 C Street, S.W., Room 2046 Washington, DC 20201 (202) 205-8102

- Head Start Bureau330 C Street, S.W., Room 2058 Washington, DC 20201 (202) 205-8573

- National Child Care Information Center301 Maple Avenue West, Suite 602 Vienna, VA 22180 (800) 616-2242 http://www.ericps.ed.uiuc.edu/nccic

- National Clearinghouse on Child Abuse and Neglect InformationP.O. Box 1182 Washington, DC 20013-1182 (800) FYI-3366 (703) 385-7565 http://www.calib.com/nccanch

- National Clearinghouse on Families and YouthP.O. Box 13505 Silver Spring, MD 20911-3505 (301) 608-8098

- Office on Child Abuse and Neglect330 C Street, S.W., Room 2026 Washington, DC 20201 (202) 205-8586

- Center for Substance Abuse PreventionNational Clearinghouse for Alcohol and Drug Information P.O. Box 2345 Rockville, MD 20847-2345 (800) 729-6686 http://www.samhsa.gov/csap

- Department of Education600 Independence Avenue, S.W. Portals Building Washington, DC 20202-6123 (800) 872-5327 (202) 401-2000 http://www.ed.gov

- Office of Elementary and Secondary EducationSafe and Drug Free Schools 600 Independence Avenue, S.W. Portals Building Washington, DC 20202-6123 (202) 260-3954

- Even Start Family Literacy Program600 Independence Avenue, S.W. Portals Building Washington, DC 20202 (202) 260-2777

- Department of Health and Human ServicesOffice of the Assistant Secretary for Planning and Evaluation 200 Independence Avenue, S.W. Hubert H. Humphrey Building, Room 415F Washington, DC 20201 (202) 690-7858 http://www.hhs.govf (http://www.hhs.gov)

- Division of Children and Youth Policy200 Independence Avenue, S.W. Hubert H. Humphrey Building, Room 450G Washington, DC 20201 (202) 690-6461

- Division of Public Health Policy200 Independence Avenue, S.W. Hubert H. Humphrey Building, Room 442E Washington, DC 20201 (202) 690-6870

- Department of Labor200 Constitution Avenue, N.W., Room S-1032 Washington, DC 20210-0002 (202) 219-8211 http://www.dol.gov

- Women's Bureau Clearinghouse200 Constitution Avenue, N.W., Room S3306 Washington, DC 20210-0002 (800) 827-5335

- Work and Family Clearinghouse200 Constitution Avenue, N.W., Room 3317 Washington, DC 20210-0002 (202) 219-4486

- Housing and Urban Development451 7th Street, S.W. Washington, DC 20410 (202) 708-1420 http://www.hud.gov

- Community Connections Information CenterOffice of Community Planning and Development P.O. Box 7189 Gaithersburg, MD 20898-7189 (800) 998-9999

- University Partnership ClearinghouseHUD USER P.O. Box 6091 Rockville, MD 20849 (800) 245-2691

- Indian Health ServiceDivision of Clinical/Preventive Services 5600 Fishers Lane, Room 6A-55 Rockville, MD 20857 (301) 443-4644 http://www.ihs.gov

- Maternal and Child Health BureauHealth Resources and Services Administration 5600 Fishers Lane, Room 18-20 Rockville, MD 20857 (301) 443-0205 http://www.hrsa.dhhs.gov

- Division of Healthy Start5600 Fishers Lane, Room 11A-13 Rockville, MD 20857 (301) 443-0509

- Division of Services for Children With Special Health Needs5600 Fishers Lane, Room 18A-27 Rockville, MD 20857 (301) 443-2350

- Division of Maternal, Infant, Child and Adolescent Health5600 Fishers Lane, Room 18A-30 Rockville, MD 20857 (301) 443-2250

- Juvenile Justice ClearinghouseP.O. Box 6000 Rockville, MD 20850 (800) 638-8736 http://ncjrs.aspensys.com

#### Nongovernmental Organizations

- American Association for Marriage and Family TherapyResearch and Education Foundation 1133 15th Street, N.W., Suite 300 Washington, DC 20005 (202) 452-0109 http://www.aamft.org

- American Public Welfare Association810 First Street, N.E., Suite 500 Washington, DC 20002-4267 (202) 682-0100

- Center for Family Life in Sunset Park345 43rd Street Brooklyn, NY 11232 (718) 788-3500

- Children's Defense Fund25 E Street, N.W. Washington, DC 20001 (202) 628-8330 (202) 628-8787 http://www.childrensdefense.org

- The Children's Foundation725 15th Street, N.W., Suite 505 Washington, DC 20005 (202) 347-3300

- Child Welfare League of America440 First Street, N.W., Suite 310 Washington, DC 20001-2085 (202) 638-2952 http://www.cwla.org

- Family Resource Coalition200 South Michigan Avenue, 16th Floor Chicago, IL 60604 (312) 341-0900

- The C. Henry Kempe National Center for the Prevention and Treatment of Child Abuse and Neglect1205 Oneida Street Denver, CO 80220 (303) 321-3963 http://www.kempecenter. org

- National Association of Child Care Resource and Referral Agencies1319 F Street, N.W., Suite 810 Washington, DC 20004-1106 (202) 393-5501

- National Black Child Development Institute1023 Fifteenth Street, N.W., Suite 600 Washington, DC 20005 (202) 387-1281 http://www.nbcdi.org

- National Center for Children in PovertyColumbia University School of Public Health Columbia University 154 Haven Avenue New York, NY 10032 (212) 927-8793 (212) 304-7100 http://cpmcnet.columbia.edu/dept/nccp

- National Center for the Early Childhood Work Force733 15th Street, N.W., Suite 800 Washington, DC 20005 (202) 737-7700

- National Child Care Information Center301 Maple Avenue West, Suite 602 Vienna, VA 22180 (800) 616-2242 Fax 1 (800) 716-2242 http://ericps.ed.uiuc.edu/nccic

- National Head Start Association1651 Prince Street Alexandria, VA 22314 (703) 739-0875 http://www.nhsa.org

- National Indian Child Care Association279 East 137th Street Glenpool, OK 74033 (918) 756-2112

- National Indian Child Welfare Association3611 SW Hood St., Suite 201 Portland, OR 97201 (503) 222-4044

- National Information Center for Children and Youth with DisabilitiesP.O. Box 1492 Washington, DC 20013-1492 (800) 695-0285 http://www.nichcy.org

- National Information Clearinghouse for Infants With Disabilities and Life-Threatening ConditionsUniversity of South Carolina Benson Building, First Floor Columbia, SC 29208 (800) 922-9234 (803) 777-4435

- National Maternal and Child Health Clearinghouse8201 Greensboro Drive, Suite 600 McLean, VA 22102-3843 (703) 821-8955

- National Parent Information NetworkERIC Clearinghouse on Elementary and Early Childhood Education University of Illinois at Urbana-Champaign Children's Research Center 51 Gerty Drive Champaign, IL 61820-7469 (217) 333-1386 http://www.uiuc.edu

- National Resource Center on Child Abuse and Neglect63 Inverness Drive East Englewood, CO 80112-5117 (800) 227-5242

- National Youth Center Network254 College Street, Suite 501 New Haven, CT 06510 (203) 773-0770 http://www.nycn.org

- Zero To Three: National Center for Infants, Toddlers, and Families734 15th Street, N.W., Tenth Floor Washington, DC 20005-2101 (202) 638-1144 (800) 899-4301 (publications) http://www.zerotothree.org

### Foundations

The following are illustrative of private foundations that provide grants for services and research regarding family-centered interventions. Grantmaker organizations such as The Foundation Center can provide information on the wide array of private foundations, corporate grantmakers, grantmaking public charities, and community foundations.

- The Carnegie Corporation of New York437 Madison Avenue New York, NY 10022 (212) 371-3200 http://www.carnegie.org

- The Annie E. Casey Foundation701 St. Paul Street Baltimore, MD 21202 (410) 546-6600 http://www.aecf.org

- The Foundation Center79 Fifth Avenue/16th Street New York, NY 10003-3076 (212) 620-4230 http://fdncenter.org

- The Ford Foundation320 East 43rd Street New York, NY 10017 (212) 573-5000 http://www.fordfound.org

- The William Randolph Hearst Foundations888 Seventh Avenue, 45th Floor New York, NY 10106-0057 (212) 584-5404

- The Robert Wood Johnson FoundationRoute 1 and College Road East P.O. Box 2316 Princeton, NJ 08543-2316 (609) 452-8701 http://www.rwjf.org

- The Henry J. Kaiser Family Foundation2400 Sand Hill Road Menlo Park, CA 94025 (415) 854-9400 http://www.kff.org

- The W.K. Kellogg FoundationOne Michigan Avenue East Battle Creek, MI 49017-4058 (616) 968-1611 http://www.wkkf.org

- The John D. and Catherine T. MacArthur Foundation140 S. Dearborn Street, Suite 1100 Chicago, IL 60603-5285 (312) 727-8000 http://www. macfdn.org

- The David and Lucile Packard Foundation300 Second Street, Suite 200 Los Altos, CA 94022 (415) 948-7658 http://www.packfound.org

- The Pew Charitable Trusts2005 Market Street, Suite 1700 Philadelphia, PA 19103 (215) 575-9050 http://www.pewtrusts.com