# Appendices

Appendix A Criteria for Establishing Levels of Evidence of Effectiveness

Appendix B Abbreviations and Glossary of Terms Used in Family-Centered Approaches to Substance Abuse Prevention

Appendix C Resource Guide