# Introduction: Scope of This Guide

This guide focuses on research and practice evidence for key environmental approaches to the prevention of problems related to alcohol availability. It evaluates the following six approaches:

1. Preventing Availability to Underage Youth
2. Raising Alcohol Taxes and Prices
3. Responsible Beverage Service
4. Changing the Conditions of Availability
5. Changing Hours and Days of Sale
6. Community-Based Prevention Approach

This practitioner's guide is intended to be brief and simple. It summarizes much of the information in its parent document, Preventing Problems Related to Alcohol Availability: Environmental Approaches-Reference Guide, and highlights information that will be most useful to those directly involved in planning and implementing prevention programs.

For much greater detail concerning the six prevention approaches, the research and practice evidence for each approach, recommendations for practice, and guides for program development, implementation, and evaluation, please see the Reference Guide.

A separate brochure-length publication, Preventing Problems Related to Alcohol Availability: Environmental Approaches-Community Guide, provides a brief overview of substance abuse problems, outlines courses of action for concerned citizens, and offers tips for becoming involved in community-centered prevention.

## Levels of Evidence

Before developing guidelines for practitioners, the evidence that comes from research and practice must be weighed. Several criteria are central to determining whether information is strong enough to serve as the basis for making recommendations.

The term research evidence refers to the research-based body of knowledge for a specific prevention approach. This information is gathered from scientific investigations that adopt various research designs but are all rigorously conducted. When natural experiments are reviewed as evidence, it is ensured that they are properly documented and analyzed.

design - an outline of the procedures to be followed in scientific experimentation in order to reach valid conclusions.

The term practice evidence describes information gained from prevention practice cases, which is generally presented in the form of well-designed and -executed case studies that include documentation on program implementation and procedures, as well as on process evaluation

effect - establishing, through comparison, a logical relationship between conditions with and without the program or intervention.

In each of the prevention approaches described in "Environmental Prevention Strategies - What Works?," shaded boxes present information on levels of evidence for the effect of intervention approaches. These boxes highlight the consensus of the Expert Panel, whose members summarized the conclusions that can reasonably be drawn after analyzing the evidence for each approach. The boxes also indicate the strength of the level of cumulative evidence supporting the conclusions.

The criteria for assigning levels of evidence are shown in the following boxes. The first three categories apply to varying degrees of confirmation of positive effect. The fourth category applies to evidence that a prevention approach is ineffective.

1. Strong Level of Evidence

Application. Practitioners can use the approach with the most assurance that the approach can produce the effect specified in the evidence statement.

Here are the criteria for including evidence in this category:

- Consistent positive results of strong or medium effect from a series of studies, including:
  - At least three well-executed studies of experimental or quasi-experimental design OR - Two well-executed studies of experimental or quasi-experimental design and consistent results from at least three case studies
- The use of at least two different methodologies
- Unambiguous time ordering of intervention and results
- A plausible conceptual model ruling out or controlling for alternative causal paths or explanations

2. Medium Level of Evidence

Application. Although the number or rigor of the studies reviewed is limited, there is substantial support for the approach's ability to produce the effect specified in the evidence statement. Practitioners should exercise discretion in applying the approach and in assessing the process and outcomes.

Here are the criteria for including evidence in this category:

- Consistent positive results from a series of studies, including:
  - At least two well-executed studies with experimental or quasi-experimental designs OR - At least one well-executed study and three prevention case studies showing statistically significant or qualitatively clear effects
- The use of at least two different methodologies
- Unambiguous time ordering of intervention and results when so measured
- A plausible conceptual model, whether or not competing explanations have been ruled out

3. Suggestive but Insufficient Evidence

Application. The approach has shown promise for the effect specified, but it is not well documented. Practitioners should be cautious about using this approach. However, if the approach fits the local situation, practitioners may use it, paying special attention to its systematic testing and documentation.

This category is used to describe research and/or practice evidence that (1) is based on a plausible conceptual model or on previous research and (2) is being demonstrated in rigorous evaluation studies or appropriate intervention programs currently in process.

- The evidence, although limited, appears to support a conclusion, but additional research is needed to fully support the conclusion. This condition often applies to areas in which there has been little study, such as those that are impractical to research or new areas of study. OR
- The evidence is associated with equivocal results. Effectiveness of the approach is supported in some studies but is not supported in others.

4. Substantial Evidence of Ineffectiveness

Application. The approach has not demonstrated the intended results or has shown negative findings for the effects specified. Practitioners are advised not to use this approach at this time.

This category describes research and practice evidence demonstrating that a prevention approach is not effective.

- The absence of a statistically significant effect in a majority of well-executed studies, including at least two quantitative studies with sample sizes sufficient to test for the significance of the effect OR
- The absence of a statistically significant negative effect in a majority of well-executed studies, including at least two quantitative studies with sample sizes sufficient to test for the significance of the effect

## Using Levels of Evidence in Program Planning

All communities endure adverse health and social consequences related to alcohol use and abuse. Many of these consequences are severe and expensive, such as automobile-related injuries and fatalities, homicides and suicides, and chronic health problems such as cirrhosis. Some of the most promising strategies for these problems are community-based prevention activities that use environmental approaches.

Reaching a single conclusion about a particular approach is difficult. No two research studies or practice cases are the same, as they differ in the subjects of evaluation and in the methods used. Conclusions from a single prevention approach may justify more than one evidence statement since the approach may have more than one desired result. Furthermore, evidence for a specific desired result may show a complex pattern. For instance, studies may show that a prevention approach has strong evidence for attaining a desired effect in the short term but suggestive but insufficient evidence for sustaining that effect over time.

Practitioners should evaluate the prevention approaches in this guide in light of local circumstances; it may not be feasible to implement only approaches with a strong level of evidence. In developing a program, practitioners must consider local needs, interests, resources, and abilities - as well as the level of evidence for a particular approach.

It takes prevention practitioners with great skill and dedication to develop strong community-based programs. Despite the difficulty and complexity of the challenges practitioners face, a growing body of research and practice evidence has documented successful strategies that can change the social, political, and economic contexts supporting alcohol availability.