# Expert Panel Leading the Development of the Guideline

- Friedner D. Wittman, Ph.D., M.Arch., Chair
- CLEW Associates
- Institute for the Study of Social Change
- University of California at Berkeley
- Berkeley, CA

- Karen Bass
- Community Coalition
- Los Angeles, CA

- Steven A. Darden
- North West New Mexico Fighting Back, Inc.
- Gallup, NM

- Manuel Espinosa
- California Alcoholic Beverage Control
- Sacramento, CA

- Darryl L. Fisher
- City Planning Department
- City of Los Angeles
- Los Angeles, CA

- Norman Giesbrecht, Ph.D.
- Addiction Research Foundation
- Toronto, ON, Canada

- Paul Gruenewald, Ph.D.
- Prevention Research Center
- Pacific Institute for Research and Evaluation
- Berkeley, CA

- Delwin Hanson
- City of Woodland Police Department
- Woodland, CA

- Ralph Hingson, Ph.D.
- Social and Behavioral Sciences Department
- School of Public Health
- Boston University
- Boston, MA

- David P. MacKinnon, Ph.D.
- Department of Psychology
- Arizona State University
- Tempe, AZ

- Linda Major
- Lincoln Council on Alcoholism & Drugs, Inc.
- Lincoln, NE

- Dennis McCarty, Ph.D.
- Substance Abuse Research Group
- Institute for Health Policy
- Brandeis University
- Waltham, MA

- A. James McKnight, Ph.D.
- Public Services Research Institute
- Landover, MD

- James A. Neal
- South Carolina Department of Alcohol and Other Drug Abuse Services
- Columbia, SC

- Francis O'Brien, Jr.
- Pennsylvania Liquor Control Board
- Harrisburg, PA

- Robin Room, Ph.D.
- Addiction Research Foundation
- Toronto, ON, Canada

- Michael Sparks
- North Bay Health Services
- Petaluma, CA

- Alexander Wagenaar, Ph.D.
- Associate Professor, Public Health
- Division of Epidemiology
- University of Minnesota
- Minneapolis, MN

- Elva Yanez
- Consultant
- Albany, CA

## Ex Officio Member

- Prakash L. Grover, Ph.D., M.P.H.
- Division of State and Community Systems Development
- Center for Substance Abuse Prevention
- Rockville, MD