# Foreword

The Substance Abuse and Mental Health Services Administration's Center for Substance Abuse Prevention, (SAMHSA/CSAP), is committed to enhancing a broad range of effective prevention strategies that are planned and implemented by State agencies as well as community-based organizations across the Nation.The Prevention Enhancement Protocols System (PEPS) generates science-based documents that can substantially improve planning and management of prevention programs, consolidate and focus prevention interventions, and serve as the foundation for potential prevention studies.

CSAP selected this topic, Preventing Problems Related to Alcohol Availability: Environmental Approaches, because alcohol problems affect many individuals and groups in our communities, and there is an emerging body of evidence that these approaches can be highly effective. In fact, research and practice strongly suggest that carefully planned management of alcohol availability can reduce alcohol problems and enhance the quality of life for all members of the community.

But many communities neglect to manage alcohol availability problems through the State and local government entities that exist for that very purpose. Through these PEPS documents, CSAP is providing State and local governments with a strong foundation for addressing alcohol problems that affect the well-being of communities, using balanced approaches involving education, regulation, and local resources for managing alcohol availability, consistent with the norms and values of the community.

PEPS designed this guide for broad use by State substance abuse agencies as well as national, State, and local organizations that try to manage the problems related to the availability of alcohol. It is intended as a practical guide for those whose responsibility it is to consider the strengths and limitations of specific interventions and to plan prevention initiatives. Using this Guide in combination with other ongoing community efforts can result in a balanced, effective program to addressing alcohol problems.

Karol Kumpfer, Ph.D. Director Center for Substance Abuse Prevention Substance Abuse and Mental Health Services Administration

Stephania J. O'Neill, Acting Director Center for Substance Abuse Prevention, SAMHSA