# Acknowledgments

The Prevention Enhancement Protocols System (PEPS) Series, initiated by the Substance Abuse and Mental Health Services Administration's Center for Substance Abuse Prevention (SAMHSA/CSAP), exists for three reasons. PEPS guides strive to

- systematically evaluate research and practice evidence on substance abuse prevention,
- make recommendations for field use by those who implement intervention programs, and
- maximize the prevention efforts of State substance abuse prevention agencies, practitioners, and local communities.

Prakash L. Grover, Ph.D., M.P.H., is the Program Director of PEPS and the Executive Editor of the Guideline series for CSAP. Robert Bozzo serves as Team Leader for the PEPS. Friedner D. Wittman, Ph.D., M.Arch., Chair of the Expert Panel, played a major role in writing the Reference Guide. He contributed to the volume beyond reasonable expectations from a Panel Chair. For this, CSAP and the Executive Editor are deeply grateful. Several other members of the Expert Panel also helped write the Reference Guide: Norman Giesbrecht, Ph.D.; Katherine Kessler, M.S., L.M.F.C.C.; Michael Sparks; Ralph Hingson, Ph.D.; and Karen Bass. From the PEPS staff, Mim Landry and Prakash Grover wrote the core sections on analysis of evidence and recommendations for practice. Cheryl Droffner provided the indispensable research assistance that serves as a foundation of such documents. Donna Dean helped refine the Reference Guide and developed the Practitioner's Guide and the Community Guide. Betsy Earp and Chip Moore, with assistance from Sara Davidson, edited the document.

Exhaustive review of the documents was conducted by Robert W. Denniston, Mark Weber, Tom Vischi, and Christine Quinn. Their comments vastly improved the document.

The deliberations and recommendations of the Expert Panel in this guide do not necessarily reflect the opinions, official policy, or position of SAMHSA/CSAP, or the U.S. Department of Health and Human Services.

This publication was prepared for SAMHSA/CSAP, with substantial assistance from Birch & Davis Associates, Inc. (Contract No. 277-92-1011). Lee Wilson served as the Government Project Officer of the Prevention Technical Assistance to States project under which this publication was produced.

For single copies of this document, contact SAMHSA' s National Clearinghouse for Alcohol and Drug Information (NCADI), P.O. Box 2345, Rockville, MD 20847-2345, 1-800-729-6686, 301-468-2600, or TDD 1-800-487-4889; or visit the website at http://www.health.org. The documents are also available electronically from the National Institutes of Health at http://text.nlm.nih.gov/ftrs/dbaccess/csap.