# Documenting and Evaluating Environmental Approaches

Prevention efforts do not end when a policy, law, or program goes into effect. To ensure that alcohol availability problems are addressed, prevention planners, practitioners, and community members need to answer two questions on an ongoing basis: (1) Was the strategy properly implemented? and (2) Is the strategy doing what it was intended to do?

To answer these questions, practitioners need to carefully plan - from the beginning - what information will be collected and how it will be used. They must collect baseline data on the community problems before intervention, data on the intervention process itself, and data on the end results.

process evaluation - a descriptive and ongoing evaluation that describes what happened as a program was started, implemented, and completed.

Assessment involves two activities: documentation and evaluation. Documentation entails keeping records, collecting data, and making observations throughout the planning and implementation processes. Its key purposes are to identify the problems, set the stage for planning and developing prevention activities, and provide the information needed for evaluating the activities. Evaluation is intended to assess the impact of prevention activities, programs, or strategies.

Although the reasons for documenting and evaluating efforts to prevent or limit alcohol availability vary according to the situation, the following reasons are common to most efforts: To better understand the associations between retail alcohol systems and alcohol-related problems. Studies may explore factors such as outlet density; rates of alcohol consumption per adult; and alcohol-related problems such as drinking and driving, crime and safety issues, and public drunkenness. To justify, plan, or develop prevention programming. Information can be gathered on alcohol availability issues such as outlet density and capacity; licensing and enforcement practices; land-use arrangements, zoning, and regulations; interaction of State and local authority and management; and community retailing environments. To manage, operate, or administer activities. An alcohol retail system may be monitored to determine whether it is being administered according to plan and whether its arrangements and procedures are appropriate for the community. To evaluate the impact of policies or programs. Studies may be conducted to evaluate the effects of specific prevention activities. These studies require both an intervention or "experimental" setting and a comparison or "control" setting, with baseline and followup data for both settings. Outlets, neighborhoods, and communities may be evaluated. To guide midcourse adjustments in prevention programming. Process or formative evaluation of prevention interventions can be used to modify prevention programs that are already under way. However, such midcourse corrections can create major complications in attributing the effects to different components of the intervention. To interpret changes over time in retail system arrangements, the role of prevention activities, and general trends in society. Activities such as building coalitions or the very process used to identify problems can be documented and evaluated to identify how prevention efforts and prevailing popular trends affect alcohol availability policies and procedures over time.

## Matching Evaluation Designs to Needs

Experimental designs often exceed the needs and resources of local efforts and are frequently nearly impossible to faithfully conduct at the community level. Practitioners may wish to consider four nonexperimental evaluation designs that are more feasible in terms of time and expense.

experimental design - a research design that included random selection of study subjects, an intervention and a control group, random assignment to the groups, and measurements of both groups.

Cross-sectional evaluation designs compare outlet density and rates of alcohol-related problems for a given area. This method can be used to establish the relationship between alcohol availability and alcohol problems, but it cannot establish cause-and-effect relationships.

Pre-test/post-test evaluation designs can measure alcohol-related problems and consumption before and after implementing the policy to evaluate whether the policy achieved the intended effects. This method can suggest simple cause-and-effect relationships. However, without a comparison group, you cannot be certain that the change was due to the intervention and not some other factor.

A time series pre-test/post-test design involves a group that is tested at least once before a policy is implemented and is retested more than once after the policy is implemented. These studies are costly and take a long time to carry out; however, they offer greater confidence that changes result from the policy, and that the measures are accurate. A stronger version of this design is when a comparison community is studied at the same time intervals without having received the intervention.

A natural study design uses both planned and unplanned changes in the environment that - while not the direct result of a prevention intervention - have an impact on alcohol availability. For example, the 1992 civil unrest in Los Angeles destroyed 200 retail alcohol outlets. The effects of this sudden decrease in outlets could then be examined. Planned natural experiments can also be evaluated for their impact on consumption and alcohol-related problems. An example of a planned natural experiment would be a State's decision to eliminate its monopoly on retail alcohol sales and allow licensed retail sales. If evaluators can respond quickly enough to such an opportunity, they may be able to collect data both before and after policy changes take place.

## Sources of Data for Analysis

Begin with an overview of the data that are readily available and a list of the data you need. For example, you can use existing data from the community to document the extent of the problem. However, special arrangements may be needed to collect data for process assessment and outcome evaluations of prevention interventions.

Data collection methods that can be used in studies of alcohol availability include the following:

- Literature reviews of alcohol availability and its associated public health and safety aspects
- Interview and questionnaire survey data obtained from patrons, servers, and the general public
- Contact with key informants and experts
- Observational methods such as visual assessments of neighborhood conditions or activities in or near licensed outlets
- Archival data on alcohol sales, drinking-related problems, and numbers and types of outlets
- Special data collected by law enforcement officers and others concerned with alcohol-related problems in the community
- Contacts with other local agencies and organizations working on this topic, as well as with State and Federal agencies, regarding the experiences of model projects elsewhere
- Legal, bureaucratic, and regulatory documents
- Data on public and media reactions to availability issues

## General Recommendations on Evaluation

At the outset of a planning or evaluation process, devote a substantial amount of time to outlining in detail the purposes and key questions or objectives of the undertaking. Focusing on the information that is most critical will help you avoid the pitfall of designing your evaluation around what data you have, not what data you need.

Whenever possible, use several methods in combination. If feasible, use both direct information - such as interviews or observations - and indirect information - such as archival data on alcohol sales and police interventions - to provide a broader data base.

Pay careful attention to the scope, coverage, validity, and reliability of the data. Know how the data are collected, stored, and organized, as well as the changes in protocols for data collection that have occurred over time that might affect the quality or comparability of the data.

Recruit and train volunteers to collect and record data. In addition to serving the needs of the evaluation, using volunteers will strengthen the community organizing effort by actively engaging participants.

Set up a routine system for collecting data to inform planning and evaluation. Setting up such a system is an effective use of resources and makes it possible to use the same data for more than one project.