# Developing and Delivering Environmental Approaches

Action on both the State and community levels is necessary to implement environmental approaches for reducing availability-related problems. The community must establish - through local legislative bodies - public policies that apply specific public health and safety standards to alcohol availability.The community must then apply the standards, on a case-by-case basis, to alcohol outlets.

Local planning and zoning ordinances offer a powerful opportunity to manage retail availability. Community members should be actively involved in developing these ordinances. Zoning ordinances can place the following limits on alcohol outlets:

On-sale and off-sale outlets can be limited to certain zones or disallowed altogether. Density restrictions can limit the number of alcohol outlets per unit of population, for a geographic area, or as a percentage of all retail alcohol outlets in a given commercial area. Spacing restrictions can specify the distance between alcohol outlets or between alcohol outlets and schools, churches, residences, parks, and playgrounds. Hours of operation can be limited. Conditions of design and operation can be established to ensure that the premises are maintained safely and securely and that appropriate practices are followed to prevent sales to underage youth, inebriates, drinking drivers, and others.

Localities can make active or passive use of their zoning ordinances. Active use involves a conditional use permit review of each application. The review is conducted through a public hearing that gives neighbors and public agencies an opportunity to identify high-risk features of the application. Passive use involves using conformance to published zoning requirements as the basis for granting a use permit.

To take action on alcohol availability problems, community members must work with police, planning, community development, and parks and recreation departments, and city attorney offices. Coordination and mutual support on alcohol guidelines can improve policy formation, enhance policy implementation, and provide clear signals and expectations for the public regarding the reduction of availability-related problems.

The four steps outlined here can help localities use their existing powers to become effective partners with the ABC authority in a joint effort to prevent problems related to alcohol availability. Each step represents a "cluster" of conceptually interrelated activities for implementing environmental approaches in communities. The activities in these steps overlap and aren't always sequential - early steps can be revisited as additional information becomes available.

conditional use permit - a permit that is granted pursuant to certain conditions, allowing the sale or consumption of alcohol.

## Activity Cluster 1: Assessment - Laying the Groundwork

Local prevention initiatives must be based on a demonstrated link between alcohol availability and community problems. Demonstrating this link helps community members connect the problems they experience to their sources and motivates them to get involved. It is also essential for the legal defense of prevention policies and any conditions that affect the use of private property.

### Identify the Problems

To characterize availability-related problems, it is important to identify and assess:

- The nature of the problems
- The physical location of the problems where the problems occur, such as at public events, certain drinking establishments, fraternity parties, or high school prom parties
- Existing regulations and procedures concerning alcohol availability
- Community attitudes about alcohol-related problems and the local history of efforts to regulate availability

### Identify the Stakeholders

Knowing who will work with you (and who will not) is essential to developing an effective strategy. Stakeholders are people with a special interest in the problem. To identify them, ask,

- Who has the power to effect change?
- Who has access to that power?
- Who is affected by problems such as drunken driving, violence, difficulties in the workplace, loitering, and neighborhood blight?
- Who has something to gain by ignoring the problems?

Particularly useful in this regard are the perspectives and duties of people who live or work in the area; owners and managers of businesses (both alcohol-related and others); and government officials and agencies, service groups, and other interested parties.

### Collect Data on the Problems

Here are some ways to build a database from both informal and formal sources. Data help demonstrate the link between alcohol availability and resulting problems. Collect data from the police, planning, and parks and recreation departments, and the State ABC to establish the extent of alcohol-related problems and incidents associated with various community environments. Use published and unpublished reports by local, State, and Federal agencies as well as newspaper coverage of alcohol-related problems in retail settings. Talk with alcohol outlet patrons, servers, and members of the general public. Observe events or activities in or near alcohol outlets. Review literature on alcohol availability and its relationship to public health and safety. Communicate with agencies, organizations, and individuals from other communities who have been active in addressing alcohol-related problems in retail settings. Talking with them can save valuable time. The very process of collecting this information can help focus energy in your own community. Use the technical assistance of individuals and agencies with special expertise. Often, their expertise is available at little or no cost. Consult some or all of the following:

- State ABC's
- The State substance abuse agency
- Local police and planning departments
- Foundations or publicly funded programs such as legal aid foundations or health planning foundations
- Federal agencies such as the Center for Substance Abuse Prevention (CSAP) and the National Institute on Alcohol Abuse and Alcoholism

## Activity Cluster 2: Planning - Organizing the Community

Well-organized groups can make significant changes in how, when, and where alcohol is sold and served. To keep organizing efforts focused and effective, all involved need to agree on the organizational approach and the role of various participants.

The composition of the groups, the model of organizing, and the issues may vary, but the underlying premise remains: Organizing the community is fundamental to effecting change.

### Identify the Scope of Action

Community organizers need to understand the differences between mobilizing for immediate action and organizing for long-term community improvement. Immediate action may demand different membership than long-term improvement. The approach also shapes how various other issues are handled. Issues of power, control, community access, and goals are all colored by the choice of organizing for immediate action or for the long haul.

### Identify Collaborators

Individuals and groups to be sought for involvement in your community effort include the following:

- Neighbors and neighborhood associations, including crime watch groups
- Local clergy
- Local or national chapters of Mothers Against Drunk Driving (MADD)
- School principals and other school officials
- Alcohol retailers and other merchants
- Community leaders and activists
- The self-help recovery community
- Social service agencies
- Advocacy groups
- Alcohol prevention agencies
- Other community service agencies

### Build Broad-Based Coalitions

Coalitions are made up of community-based organizations and smaller, less formal grassroots groups that share common goals or concerns. Coalition-building is an expanded form of community organizing. The more the coalition represents the various facets of community that share a common goal, the more powerful and respected it will be.

fortified wine - a wine that has had alcohol, usually in the form of grape brandy, added to it either during or after fermentation.

### Identify High-Risk Outlets

Efforts that focus solely on individual problem outlets or drinkers have proven inadequate. Broader prevention strategies are needed that set policies, formulate ordinances, and affect the environments where alcohol is available - especially high-risk environments.

High-risk outlets endanger public health, safety, and well-being. In general, high-risk outlets engage in one or more of the following activities:

- Allowing aggressive sales practices (sales with the intent to intoxicate)
- Selling to underage youth
- Selling to obviously intoxicated persons
- Contributing to, or neglecting to address, drug trafficking on the premises
- Encouraging or allowing loitering near or on the premises
- Neglecting to address on-site consumption of alcoholic beverages from open containers in an off-sale outlet or on the premises
- Not providing proper lighting or failing to institute other crime prevention methods in known high-crime areas
- Violating license restrictions on hours or days of sale
- Marketing beverages such as fortified wines
- Using promotions that encourage overconsumption, such as two drinks for the price of one
- Ignoring problematic patron behavior
- Resisting working with the police and neighborhood groups to address complaints

### Mobilize Neighborhoods

Organized pressure from the community can have an impact on high-risk outlets that fail to comply with existing enforcement efforts. Community organizers can try to meet with the owners of each high-risk outlet and remind them of the stature they stand to gain by helping keep the community safe and of the license they risk losing if they refuse to take corrective approaches.

Working with high-risk outlets in areas such as inner-city or high-poverty neighborhoods, a collaboration of residents, churches, businesses, and social and health service programs can bring about improved compliance and enforcement, as well as the creation of stronger ordinances and public policies. Local groups can also obtain relief through small claims court, by demanding vigorous nuisance-abatement and code-enforcement activities, and by obtaining stronger zoning laws for the regulation of alcohol availability.

problem outlet - a retail alcohol outlet that resists cooperation with authorities or community groups in addressing high-risk practices or community complaints.

### Use Tragedies as a Mobilizing Force

Sometimes it takes a tragedy to motivate a community to take action. Tragedy-based organizing occurs in communities that are frustrated by the persistence of availability-related problems and the seemingly inadequate official response to them. An excellent example is MADD, started by Candy Lightener after her daughter was killed by a thrice-convicted drinking driver. If a tragedy occurs, practitioners should use it to mobilize the community.

### Use Media Advocacy

The news media offer a very powerful tool for defining and publicizing needed change. Media advocacy can make a significant impact on citizens' views about alcohol-related problems and solutions. Media advocacy combines community organizing, public policy support, and the use of several media sources (radio, TV, newspaper) to promote specific prevention policies and to influence policymakers to make changes.

### Check Your Progress

Answer the following four questions to gauge the effectiveness of your community organization effort:

1. Is the community selecting reduction of alcohol availability problems as a concrete objective that everyone will work to support?
2. Has the community developed a productive planning process that achieves results?
3. Is your group obtaining professional expertise and integrating your program with public agencies in the community?
4. Does the group adequately explain the local community's problems to the larger community, and does it take part in the larger community's political process?

## Activity Cluster 3: Implementation - Moving into Action

Taking action means bringing about changes to availability-related practices and policies. Whatever their scope may be, all such changes will involve three groups of stakeholders: the owners and managers, the occupants and neighbors, and the officials and other interested parties. Each of these three stakeholder groups exerts a particular kind of influence on activities associated with the alcohol outlet(s) in question.

Owners and managers operate the alcohol environment. They determine who may enter, and who may stay. They design the environment and manage the staff who operate it. They set the rules for patron and guest behavior while in the establishment or attending the event where alcohol is present. These rules include provisions for the exit of staff, patrons, or guests if their behavior is not acceptable. The owners and managers also are legally and financially responsible for the environment.

Occupants and neighbors use the environment. Their uses of the setting and behaviors at the event establish the kind of activities and quality of experiences associated with the alcohol environment. Although the adult occupants and neighbors are fully responsible for their individual behavior in connection with these activities, they are also influenced strongly by the behaviors of other occupants and neighbors and by the rules and expectations of the facility's management.

Officials and other interested parties have particular obligations or interests in controlling the environment. For example, State ABCand local police officials are responsible for enforcement to protect public safety. Public health officers and social service providers are responsible for guarding against threats to public health and well-being posed by the environment. Banks and insurance companies are concerned that the establishment's financial operations are sound and legitimate.

Because the actions of these three stakeholder groups are so closely connected in the local community, successful adoption of changes in alcohol practices and policies for alcohol availability will require deliberate and continuing efforts by the three stakeholder groups to work well with each other.

### Establish Task Forces

It is important to move into action on specific alcohol problem environments through the organized efforts of a community action group, as described in Step 2. The community prevention worker can provide coordinating and communication assistance help to form a task force or working group dedicated to realizing the prevention initiative that has been selected and specified through Steps 1 and 2. The community prevention worker can also help with special technical assistance that may be needed. For example, a task force dedicated to establishment of an effective Responsible Beverage Servicetraining program may need a technical committee to identify the best training curriculum.

The community action group's other components are vital to help facilitate the task force work upon which the three stakeholders are engaged. For example, these other components of the community planning effort may include a Steering Committee to help with liaisons to key agencies and organizations and with monitoring and evaluation of prevention efforts, a Public Information Committee to create press coverage and other community education activities, and a Planning Committee to build a broad base of community support and understanding for the initiative.

### Tasks for Community Members

Maintain active participation. Stay involved in the policymaking and monitoring process. The ongoing participation of concerned community groups and organizations is critical to success.

Continue to learn about alcohol availability in your area. Help document the pattern of problems at high-risk establishments and the impact of alcohol availability on the health and safety of the community.

Provide critical support. Community organizations can provide facilities, spread information, and recruit volunteers. Solicit the support of the local business community.

### Tasks for Business Owners and Managers

Engage in self-monitoring. Businesses should monitor their compliance with local policies. This process will enhance their credibility in the community and will be extremely helpful in addressing problems created by noncompliant outlets.

Help develop policy procedures. Owners and managers should meet periodically with city agencies and community groups to jointly construct the required steps and establish a timeline for compliance with local policies. This approach brings businesses into the decision-making process.

### Tasks for Local Officials and Other Interested Parties

Clarify standard review procedures. Local legislation and regulations should be followed up quickly with instructions and guidelines that explain the procedures for reviewing use permit applications from alcohol outlets. Trained staff should be available to explain the procedures.

Monitor operations and reward compliance. Perform unannounced compliance checks to determine whether outlets are selling to minors or violating other restrictions specific to the community. The community also should reward merchants who consistently comply with the law by acknowledging and publicizing their efforts.

Train staff. Coordinate staff training at the various agencies that implement alcohol policies.

Educate participants and support broad participation. Local public agencies are responsible for educating community groups and explaining how to participate in the review process. Planning and police departments should educate alcohol retailers and guide them through the procedures for special-use permits. Other efforts include introductory workshops for community groups, retailers, and other organizations; pre-application and pre-enforcement meetings; specialized briefings for those in high-risk areas; and building community support through media advocacy.

Encourage responsiveness, promptness, and efficiency. The review process should be a practical tool for preventing alcohol-related problems. Protection of health and safety require prompt, efficient action. Implementation of policies should include creative modifications of standard review procedures to eliminate elements that have little preventive value or objectives that can be accomplished by other means.

Collect local data. Most local data systems were not designed to document problems related to alcohol availability. However, systems can be redesigned to provide minimal but appropriate data to permit statistical operations needed to demonstrate the prevalence of alcohol-related problems, as well as to track progress over time.

Provide prompt and fair enforcement. The police often do not have sufficient staff to effectively monitor and enforce compliance with availability policies. However, several community actions can help, and the police can work with community groups to identify and document problems. For example, the community can set up a community-wide, user-friendly complaint system. Negotiate with retailers before applying sanctions; apply sanctions firmly and promptly when necessary.

Offer economic incentives. Local action to help retailers reduce their dependence on alcohol sales will depend on the community's creativity and economic conditions. For example, communities may encourage patronage of outlets that shift away from the sale of high-risk alcoholic beverages. Local economic development offices may be able to offer incentives that help retailers make these shifts.

Work with other stakeholders. Inform insurance companies, national owners of local chain outlets, investors and note holders, and other parties of the community's alcohol availability policy and ask them to endorse it for their operations in the community.

The following table presents examples of roles and responsibilities of local public agencies in managing alcohol availability and related problems. In a given setting, these roles and responsibilities will be determined by the change-agent, the community, and the existing organizations and their commitment and resources.

Institutionalization - occurs when a policy or program is supported by the community and local or State governments and incorporated in routine operations.

## Activity Cluster 4: Continuity - Institutionalizing Policies

Institutionalizing a policy means incorporating it into an agency's or community organization's routine operations. Alcohol availability policies should be reviewed continually to determine whether they still address the problems they were intended to solve. A policy should be responsive to changing demographics and shifting business climates in its community.

Of the six prevention approaches presented in this guide, these four require institutionalization activities:

- Preventing Availability to Underage Youth
- Responsible Beverage Service
- Changing the Conditions of Availability
- Community-Based Prevention Approaches

Institutionalizing local availability policies is challenging. Policies that have been fully adopted and produce useful results are likely to gain acceptance. Conversely, failure to diligently implement a local availability policy can damage its credibility, even though it may be essentially sound. Even after a policy is successfully implemented, people may lose sight of its preventive value and begin to wonder why the community should bother to maintain it. For all these reasons, it is critical to regularly review policies relating to alcohol availability.

### The Review Process

The review process should be driven by positive concerns for improving the policy's effectiveness and efficacy. The ongoing review process involves the following examinations: Are administrators of an alcohol availability policy responsive when availability problems are identified? Is there a system to gather and analyze specific information related to alcohol problems and then to distribute or make that information available to the appropriate parties? Do official records accurately reflect and thoroughly note the nature of community-based complaints about problem outlets? When problems are identified, are managers made aware of them? Is the policy fairly, uniformly, and appropriately applied? Alcohol availability policies must be administered to address real problems and must be applied in a nondiscriminatory manner. Is the policy easy to administer? Experience may show that the original policy is difficult to implement or that it does not function as intended. Changes in operating conditions and personnel in local organizations and government bodies may also require adjustments. The search for improvements in administration should be continuous. Modifications to the policy should always be welcome when they make administration easier without diminishing effectiveness. Does the policy use recent research findings regarding the link between public health and safety problems and alcohol availability? Findings from this research should continue to flow into local policymaking activities. The research should serve as one starting point for continuing examinations of the policies currently in place. Does the policy review process include community feedback? Seeking comments and advice from the community makes for an informed and active community. In such communities, it is more likely that local organizations and private citizens will be able to speak clearly about the effect of availability policies and in turn develop an ownership of these efforts.

Periodically convening a community group dedicated to the prevention of availability-related problems will do much to renew the policymaking process indefinitely. One way to stimulate the formation of such a group is to require an annual or biannual report from the city manager to the city council. This report should describe progress and outstanding issues and could serve as the agenda for a community meeting.

Roles and Responsibilities of Local Public Agencies

Department or Agency | Chief Responsibility | Staff | Responsibilities
City attorney's office | Ensuring that procedures and practices apply applicable laws at State and local level in ways that are most advantageous to the locality. | Senior attorneys | Review interaction between State's and locality's regulations of alcoholic beverages to provide basis for resisting legal challenges to locality's authority to regulate land use where alcohol is sold and (where permitted by the State) to regulate sale of alcoholic beverages Monitor legal issues and identify effective alcohol ordinances in other localities
City/county manager's office | Coordination of contacts among all of the agencies and reporting of their activities to the local legislature. Central planning and review function helps ensure that all departments coordinate their efforts and respond appropriately to retailers and concerned community organizations regarding alcohol-related problems. | Senior management personnel | Coordinate work regarding alcohol availability across all of the locality's departments Establish task forces and alcohol policy working groups.
Police or sheriff | Problem description and enforcement activities in relation to all alcohol availability and drinking in public rights-of-way. | Patrol division, Crime analysis unit, Chief's office, community-centered policing program, vice unit. | Report alcohol-related problems Document link between problems and availability Work with State ABC, interpret availability-related problem data, negotiate approvals and denials of permit applications Carry out proactive compliance and mitigation activity such as decoy-buy operations, preventive visits to outlets and neighborhood groups, consult with outlet operators and other agencies on crime prevention and compliance issues
Planning and zoning | Approval and monitoring of distribution and operation of retail outlets throughout the community | Line staff in zoning Code enforcement staff Long-range land use planning staff | Review department applications and make recommendations to zoning approval boards Ensure compliance to conditions imposed by approval process code enforcement reviews and nuisance abatement activities at outlets Establish an "alcohol outlet desk" to focus and coordinate activities and to respond rapidly to queries Use conditional use permits and other land-use measures to reduce high outlet densities, facilitate case-by-case oversight, and establish preventive conditions
Parks and recreation, community services | Sales of alcohol at special events and in public places (in cooperation with sheriff's department) | Maintenance personnel Program staff | Provide information about substance abuse in parks and facilities Review special-use permit requests for alcohol sales, provide information to users of parks and facilities about alcohol use policies, monitor events at which alcohol sales are permitted Set standards for alcohol use at public events
Housing and community services | Alcohol-related domestic violence | Key Staff | Work with landlords to develop policies to prevent problems Assist police and social service domestic violence teams to work with apartment management and residents
Agency for business licenses and permits | Collection of permit fees and use-permit application fees | Key Staff
Community economic development agencies | Examine costs and benefits of alcohol outlets as participants in community development projects | Key Staff | Establish fees levels for city services to reflect the greater costs of alcohol outlets for police services and land-use administration Establishing "alcohol outlet elements" in redevelopment plans