# Environmental Prevention Strategies - What Works?

In an environmental prevention model, the focus on solving alcohol-related problems shifts from an individual focus to an environmental focus.The logic is that reducing alcohol availability will reduce alcohol consumption or modify the conditions under which it is consumed, which will in turn reduce alcohol-related problems such as violence, traffic injuries, and alcohol consumption by minors.

- Individual focus
- Individual behaviors
- The relationship between the individual
- Short-term program development
- Individual participation in problem-solving

- Environmental Focus
- Policy and policy changes
- The social, political, and economic and alcohol-related problems contexts of alcohol-related problems
- Long-term policy development
- Collective action

As the PEPS Expert Panel evaluated research studies and practice cases, it grouped the evidence into six prevention approaches. Each approach is presented here in terms of its concept, the activities of the studies reviewed by PEPS, the strength of the evidence supporting the approach, lessons learned from the evidence, and recommendations for practice.

## Prevention Approach 1: Preventing Availability to Underage Youth

How do minors get their hands on alcohol? They get it from friends and family members, they shoplift, and despite a minimum legal drinking age of 21 they buy it directly from retail outlets such as convenience and grocery stores, service stations, and minimarts. Enacting and enforcing laws prohibiting alcohol sales to underage youth should reduce the likelihood that merchants will sell alcohol to minors, who will in turn be less likely to try to buy it.

### Activities of the Studies Reviewed

- Establishing or modifying State laws regarding the minimum legal drinking age
- Establishing State laws for blood alcohol concentration (BAC) limits that are different for minors and adults
- Enforcing State laws regarding the minimum legal drinking age

lessons learned - in this guide, conclusions that can be reached about a specific prevention approach based on the research and practice evidence.

### Lessons Learned

- Merchants and minors often ignore the laws restricting alcohol sales to minors. Community-based prevention efforts can educate and publicly support merchants who comply with drinking age laws.

Levels of Evidence: Availability to Youth

The research and practice evidence reviewed indicates that it is possible to implement and enforce laws designed to prevent alcohol availability to minors.

- There is medium evidence that increasing the minimum drinking age results in a decrease in consumption of alcohol and consequent alcohol problems other t han traffic casualties.
- There is strong evidence that there are substantial sales to minors and t hat there is considerable potential for reduction of such sales.
- There is medium evidence that the level of enforcement affects the rates of underage purchasing.
- Most Americans who drink alcohol begin in their early teens. Occasional intoxica tion for many begins during the mid-teen years. Recurrent drinking to intoxicati on is quite common among college students. It is clear that enforcement of minim um drinking age laws decreases but does not eliminate underage drinking.
- The enforcement efforts with the greatest immediate public health significance a re those that break the link between drinking and driving.

All the prevention approaches presented in this guide should be considered in view of their suggested application in the Evidence Boxes (pp. 2-3). However, local needs, interests, resources, and abilities - as well as the level of evidence - must all be considered as practitioners develop their programs.

### Recommendations for Practice

Enhance enforcement. Laws that increase the minimum drinking age help to decrease alcohol consumption, traffic casualties, and alcohol problems. However, these laws are not uniformly enforced and are often poorly enforced. Therefore, practitioners should focus on enforcement. Efforts can include creating linkages among several groups: the State ABC board, the local police, college administrations, and others that promote community values and support strict enforcement of drinking-age laws.

Unite efforts. A high minimum drinking age is more effective when it is complemented by adjunctive efforts such as implementing land use laws consistent with the enforcement of drinking-age laws.

Be consistent. The enforcement of minimum drinking-age laws differs among communities and is affected by many factors, such as the police department's service level or workload, community priorities, and availability of funds. Community laws and enforcement policies should be consistent with local prevention messages.

Anticipate crises. The enforcement of minimum drinking-age laws is often driven by tragedies and crises. Anticipate crises that could occur during special events such as rock concerts, high school and college activities, and holidays. Many fraternities and sororities have activities that revolve around drinking alcohol. These activities often escape the scrutiny of community and university law enforcement agencies and university administrations until a tragedy occurs. Work to prevent such tragedies by gaining the support of fraternities and sororities to change norms that promote heavy drinking. If the local chapters will not cooperate, enlist the support of their national organizations and their insurance companies.

Educate underage youth. Most young people harbor false beliefs about alcohol and driving impairment. Many think it would take several alcoholic drinks or many beers to impair their driving. Research shows that one or two alcoholic drinks or four or five beers often produce blood alcohol concentrations in excess of the legal limit. Even with low to moderate blood alcohol concentrations, younger people are more likely to be in traffic crashes when drinking alcohol. This message needs to be brought home to teenagers.

## Prevention Approach 2: Raising Alcohol Taxes and Prices

When States add new taxes that raise the price of alcohol, researchers have the chance to study how the increased cost affects purchase and consumption rates. The assumption is that significant increases in price will make alcohol less accessible, especially to youth. On the other hand, "two for the price of one" or other happy-hour promotions are thought to increase the likelihood of overconsumption.

### Activities of the Studies Reviewed

Most of the studies reviewed in this approach were not planned interventions developed by public health practitioners but, rather, the observations of "natural experiments." Natural experiments are changes - such as new State taxes on alcohol - that offer researchers an opportunity to compare behaviors before and after the changes take effect. Some of the factors that researchers examined in this prevention approach are changes in State and local taxes on alcohol; minimum legal drinking age; retail prices of wine, beer, and distilled spirits; and happy-hour drink discount policies.

### Lessons Learned

Increased alcohol taxes are associated with a moderate decrease in alcohol consumption, as well as alcohol-related problems, and can be an important aspect of a prevention campaign. Some research even revealed that, among underage youth, taxes that increased price were more effective in reducing consumption than a minimum legal drinking age.

### Recommendations for Practice

Levy local taxes. Where State laws allow, local taxes such as a "nickel-a-drink" tax for on-site purchases may be an effective way of both financing local alcohol prevention initiatives and dissuading purchase. Local license fees may also be employed to increase alcohol prices.

Index State taxes. Because the benefits of price increases resulting from State alcohol taxes are likely to diminish as inflation erodes the real value of the tax increase, the taxes can be indexed so that the nominal tax rates rise in step with prices. Indexing alcohol taxes to the consumer price index is an effective way to maintain the public health gains of higher taxes.

Seek allies in neighboring jurisdictions. Practitioners who are considering promoting alcohol taxes should initiate discussions and possible collaboration with neighboring jurisdictions. The benefits of State alcohol taxes erode when the strategy is out of step with that of neighboring jurisdictions. Cross-border shopping, cross-border drinking and driving, theft, and black-market sales may result. When neighboring jurisdictions adopt equivalent regulations, such problems greatly diminish.

Levels of Evidence:Taxes & Prices

The research evidence reviewed indicates the following:

- There is strong evidence that increases in alcohol taxes result in a moderate decrease in alcohol consumption.
- There is strong evidence that increases in alcohol taxes result in a moderate decrease in alcohol-related problems such as automobile crashes, cirrhosis mortality, and driving under the influence.
- There is medium evidence that increases in alcohol taxes result in roughly equivalent reductions in consumption of alcoholic beverages among all drinkers.
- There is suggestive but insufficient evidence that increases in alcohol taxes have a strong effect on drinking initiation among youngsters.
- There is suggestive but insufficient evidence that happy-hour promotions increase alcohol consumption.

## Prevention Approach 3: Responsible Beverage Service

The behavior of people who serve alcohol and the policies of drinking establishments can influence the behavior of the patrons. For example, servers may encourage heavy drinking; allow heavy drinking to continue ignored, promoting intoxication; or foster problems associated with intoxication, such as disruptive behavior, fights and resulting injuries, or driving while intoxicated (DWI). Training servers and management to watch for and recognize the warning signs of intoxication can help reduce the risk that patrons will become intoxicated and harm themselves or others. It may be necessary to modify management policies to discourage an atmosphere of "anything goes."

### Activities of the Studies Reviewed

- Conducting responsible server training programs
- Establishing a State law requiring responsible server training
- Enforcing a county law prohibiting alcohol service to intoxicated patrons
- Establishing a State Liquor Control Board with comprehensive prevention activities
- Establishing a coalition of representatives from the hospitality industry and the prevention field to promote and ensure responsible beverage service

Levels of Evidence: Responsible Beverage Service

The research and practice evidence reviewed indicates that it is possible to implement responsible beverage server interventions:

- There is strong evidence that server training and policy interventions are effective in curbing illegal sales to intoxicated and underage individuals when these interventions are combined with enforcement activities.
- There is medium evidence that server training and policy interventions are effective in improving some forms of server behavior, at least in the short term.
- There is medium evidence that server training can lead to more responsible service practices and management policies.

### Lessons Learned

- Server training programs differ in type, intensity, length, and focus. There is no evidence that certain server training program characteristics are associated with greater or lesser effectiveness.
- Server training programs are more likely to exist when stakeholders (people with a special interest in the problem) offer support, organization, and interest.
- States, counties, and other local jurisdictions are appropriate vehicles for establishing server training programs.
- Responsible beverage service programs are most likely to succeed when servers and managers know that the law will be enforced or realize that they assume significant liability if they serve intoxicated or underage individuals.

### Recommendations for Practice

Enforce the law. All States and most local jurisdictions have laws regarding the sale of alcohol to underage and intoxicated individuals. These laws should be enforced strictly and uniformly.

Target trouble spots. Focus on high-risk establishments and training their staffs. High-risk establishments include the locations where arrested drunk drivers purchased their last drink. Much of the information for such training can be collected by police during arrests, by counselors during hearings, or by those training drivers convicted of DWI.

Keep the legal burden on owners. The strongest incentive to stop owners from serving intoxicated or underage individuals in their establishments appears to be revocation of the establishment's alcohol license. Owners are also concerned with preventing injuries for which they might have civil liability. In a few States, this liability has, unfortunately, shifted from owner to server. States and jurisdictions should try to keep - or even increase - the burden of legal responsibility on the owners, not their employees.

Provide incentives. Drinking establishments often need incentives to participate in responsible beverage service activities. Prevention approaches should include incentives regarding license retention, legal liability, reputation, etc. Practitioners can highlight such incentives through persuasive statements such as these:

"You don't have to worry about losing your license to sell alcohol if you never sell it to intoxicated or underage individuals." "You protect yourself from legal liability arising from the behavior of impaired patrons if you never serve anyone to the point of intoxication." "You'll be known as an establishment with a good reputation if you help keep the community safe and healthy by doing your part to prevent alcohol abuse, addiction, and alcohol-related problems."

Intervene early. Early intervention (to revoke alcohol licenses) is more effective than waiting until the problems associated with a drinking establishment have progressed to a late stage.

Close license loopholes. When the State or jurisdiction revokes a license, the license should not be allowed to transfer to a new owner - often a friend or relative. Potential new owners should have to apply formally for a new license.

Avoid grandfather exceptions. Licenses should not transfer to a new owner unless all restrictions that apply to new licenses apply to the purchase of the existing business.

Help establish standards for beverage service activities. At this point, there are no clear national standards. Certain national organizations and State agencies are working to define what components are essential, optimal, and effective. Server training should be understood as one component of responsible hospitality, which encompasses the following actions:

- Developing community norms on the principles and practices of responsible hospitality
- Instituting professional development programs that train management and service staff in responsible hospitality
- Providing information and training for organizers and volunteers at community events
- Developing guidelines for employers and social hosts
- Consistently enforcing regulations governing the sale and serving of alcoholic beverages
- Creating positive incentives to recognize and reward businesses and events that practice responsible hospitality

Be sure alternatives to alcohol are offered. Managers of sales establishments often see food and nonalcoholic drinks as less desirable because they are less profitable. Responsible beverage service programs should encourage managers and servers to provide these products. Such services encourage the use of designated sober drivers and reduce intoxication.

Provide continuous server training. There is significant turnover among alcohol servers. As a result, continuous server training should be offered for entrants into the business as well as for experienced servers, who can benefit from refresher sessions.

## Prevention Approach 4: Changing the Conditions of Availability

Alcohol availability is associated with social, civic, and health problems and can be modified through government and community actions. These actions include two distinct dimensions:

- Controlling outlet density and restricting days and hours of alcohol sales
- Restricting availability of alcohol at sporting and recreational events, as well as at special locations such as parks and other publicly owned facilities

While both aspects of this prevention approach are important, substantially more research is needed on the second (i.e., restricting availability at special events and locations).

### Activities of the Studies Reviewed

The studies reviewed in this approach evaluated outcomes of "natural experiments," including changes in legislation regarding alcohol sales restrictions and regional differences in laws that allowed comparison between regions. Some of the changes involved the following activities:

- Eliminating State and provincial monopolies and privatizing retail alcohol sales and wholesale alcohol sales and distribution
- Changing a State law to remove off-sale restrictions on the sale of wine and beer near campuses
- Comparing differences in county-level prohibitions and State and local laws, regulations, and policies pertaining to: liquor sales, distribution methods, minimum legal age for purchase, and licensing of off- and on-premises alcohol outlets
- Comparing differences in county and city ordinances that range from liberal to rigid control over outlet density
- Instituting a law permitting grocery stores to sell table wine products

The following activities were examined in studies and practice cases concerning alcohol availability at special events and locations:

- Provincial regulations permitting the sale of beer at sporting events
- Use of alcohol at city-owned recreational properties
- Municipal policies regulating alcohol sales at specially licensed social and recreational events in city-owned or -managed facilities
- Community policies that establish alcohol rationing, prohibit public drinking, and disallow congregating at parking lots and campgrounds

Levels of Evidence: Conditions of Availability

The research evidence reviewed indicates that it is possible to implement efforts that result in changes in alcohol availability.

- There is medium evidence that an increase in the number of outlets per capita increases rates of alcohol consumption and alcohol-related problems.

The research and practice evidence reviewed indicates that it is possible to pass legislation regulating the sale and consumption of alcohol at special events and locations.

- There is suggestive but insufficient evidence that controlling alcohol availability and training servers in sporting arenas and at special events reduces the number of intoxicated persons and the rate of abusive incidents involving intoxication.

### Lessons Learned

- Alcohol consumption levels and the rates of alcohol-related problems tend to increase when a greater density of outlets and increased hours of sale increase the availability of alcohol.
- Although there is a clear relationship among alcohol outlets, high poverty rates, and violence, the location and density of outlets are themselves related to community power. For example, zoning laws often keep liquor stores and high-risk businesses out of affluent neighborhoods.

The following lessons pertain to the regulation of alcohol availability at special events and locations:

- A wide range of restrictions can be placed on special events, including restrictions on operating hours, noise levels, general location of event, location of alcohol sales or places of consumption (such as beer gardens), advertising of alcohol, alcohol sponsors, age of servers, quantity of sales, size of containers, and condition of the customers.
- Alcohol sales can be discontinued before an event is over, giving patrons some time between their last drink and driving home. For example, alcohol sales can be discontinued at the end of the third quarter of a football game. Sales of food and nonalcoholic beverages can be required during and after alcohol sales are cut off.

### Recommendations for Practice

The following recommendations of the Expert Panel address general issues such as geographic spacing of outlets and community compatibility.

- Collect data on outlet density. When communities perceive problems related to outlet density, it is important that they initiate a data collection effort using individuals with skills in data collection and analysis. Important information that should be gathered includes police activities, citizen complaints, and State licensing complaints.
- Become aware of licensing laws and processes. Community prevention groups should become involved in issues such as density and spacing. They also need to become aware of licensing laws and ways in which citizens can become involved in the law-changing process. Laws are not changed unless there is involvement and activity on the part of those who are affected; often, it is the community that makes the difference.
- Consider neighborhood compatibility. A specific outlet may be incompatible with the surrounding area. For instance, an outlet may be incompatible with other businesses or local residents - perhaps due to late-night entertainment or hours of closing. The Expert Panel recommends that all new applicants be interviewed by representatives of local residents and businesses and be able to demonstrate to the city or licensing body that the immediate neighborhood does not object to the business.

The following Expert Panel recommendations regarding regulations at special events and locations address general issues such as alcohol control activities at community events.

- Plan ahead. Introduce discussions about alcohol control activities, providing nonalcoholic beverages, and alcohol safety provisions early in the planning stages of community-sponsored festivals, street fairs, and other special events.
- Train servers. Make sure that the people who will serve alcoholic beverages at special events receive server training, understand relevant laws and policies, and know the guidelines for resolving problems.
- Disseminate rules. Develop simple guidelines for alcohol activities before special events and publicize them through signs, brochures, and printing of rules on tickets.
- Use physical visual aids to separate drinking adults from nondrinking ones. Providing nondrinking "family areas" decreases alcohol-related incidents. This approach also attracts family customers who may otherwise stop attending functions because they object to incidents of drunken rowdiness. Hand-stamping adults or giving them identification bands as they enter special events helps to enforce no-sales-to-minors laws.
- Educate promoters. Alcohol-related problems at sporting events, rock concerts, and other large special events can be categorized into two types. The first type includes unpleasant behavior, rowdiness, fights, and personal and property damage that occurs at the site before and during the event. The second type includes arrests for DWI, driving casualties, street fights, and other incidents that occur after and away from the event site, often on the way home. Promoters are more likely to pay attention to the first type. Fewer promoters adequately address the second type. Prevention practitioners can sensitize promoters to the second type of problems and the promoters' potential contribution in reducing them.
- Address the need for a balance of interests. Permitting and controlling alcohol use at sporting and special events involves balancing several needs and concerns. Alcohol sales are a substantial source of profit for stadium owners, sports teams, and catering companies. If alcohol-related problems become numerous and severe, however, attendance may suffer and liability issues can arise. Community interests can influence private profit interests, helping all concerned to work together to achieve an acceptable balance.

Level of Evidence: Hours and Days of Sale

The research evidence reviewed indicates that, in relation to changes in the days and hours of alcohol sales:

- There is medium evidence that expanding the hours or days of alcohol sales increases the rates of alcohol consumption and alcohol-related problems.

## Prevention Approach 5: Changing Hours and Days of Sale

Governments often influence the availability of alcohol by specifying the hours of sale at specific sites and by allowing sales only on certain days. Although seldom designed for prevention purposes, such changes are natural experiments that provide opportunities to examine the effects on overall alcohol sales and patterns of consumption.

### Activities of the Studies Reviewed

The studies reviewed evaluated outcomes of natural experiments resulting from changed alcohol sales laws. These changes included the following:

- Increasing, decreasing, or shifting the hours during which taverns can sell alcohol
- Prohibiting Saturday sales at wine and spirits shops

Most of the research in this area reflects recent experience with extending rather than reducing hours or days of sale and is based on research conducted outside the United States.

### Lessons Learned

- Alcohol consumption levels and rates of alcohol-related problems tend to increase when the hours and days of sale increase.
- Reducing availability is difficult in an era when consumer convenience is such a high priority. Even though one experiment (in Norway) demonstrated clear positive results from Saturday closing, the political support was lacking to continue or extend the closing.

### Recommendations for Practice

Know the law. It's important for communities to be familiar with State and local laws regarding hours and days of operation.

Be alert for chances to make the case for limited availability. Knowing the law will enable communities to recognize and take advantage of opportunities to exercise control.

Be alert to seemingly minor or innocuous changes in availability. Proposals to extend hours or days of sale should be evaluated in light of the fact that it is nearly impossible to reverse such changes.

## Prevention Approach 6: Community-Based Prevention Approach

Community-based initiatives to change local laws, regulations, or policies offer a powerful resource for decreasing alcohol availability and the accompanying alcohol-related problems. (This approach combines the most promising elements of the other five approaches.)

### Activities of the Studies Reviewed

- Launching a comprehensive prevention program that included mass media programming, a school-based education program, parent education, community organizing, and health policy development components
- Developing a community coalition of merchants, police officers, and community organizations
- Organizing a public education campaign led by a local council on alcoholism and drug abuse in concert with the hospitality industry and community-based prevention groups
- Setting up a coalition that included a city planning committee, the city council, and other city agencies working in concert with a university-based prevention institute
- Conducting a mass media advocacy program

### Lessons Learned

The following are lessons learned and conclusions that can be drawn from the research and practice evidence reviewed for this approach.

- Community-based activities to control alcohol availability can lead to the development of other alcohol-related prevention activities.
- Community-based activities to control alcohol availability can be used to enhance the effectiveness of prevention programs aimed at reducing drinking by individuals.
- Ad hoc coalitions can result in the establishment of permanent entities for maintaining policy changes on alcohol availability and developing other prevention activities.
- Community organizing initiatives can be combined with mass media campaigns to increase coverage of and debate on alcohol availability issues and proposed changes in local laws, regulations, or policies.

Levels of Evidence: Community-Based Approach

The research and practice evidence reviewed indicates that community-based approaches can produce coalitions that include multiple partners and address diverse issues:

- There is strong evidence that community-based prevention activities can result in decreases in alcohol consumption.
- There is suggestive but insufficient evidence that these programs can diminish driving after drinking, traffic death and injury, and speeding.

community based prevention - a prevention approach that relies on several interventions in concert, involving various sections of the community, drawing on multiple local resources to address a community problem.

### Recommendations for Practice

It is important to note that, to be effective, coalitions need the participation of the retail and wholesale beverage industries.

- Use multiple, integrated strategies. Multicomponent, community-based strategies are more effective than single-component strategies. The individual components of a multicomponent strategy strengthen, complement, and support one another. Multicomponent strategies create an additive effect that is greater than the sum of the individual components. Also, in the undesirable event of one component having to be eliminated, the remaining components may continue to exert a significant preventive effect. For example, in the area of responsible beverage service, a multicomponent strategy could include mass media promotion, server training, drinking establishment management policy and procedure development, community monitoring to observe whether outlets serve intoxicated patrons and card youthful patrons, and collaboration with law enforcement to take action against offenders.
- Develop ongoing support for change. Supporting change is just as important as initiating it. Community coalitions that focus only on the implementation of a policy or regulation will often see their gains diminish unless they pay attention to sustaining the policy changes and related prevention activities.
- Continuously cultivate membership. Prevention practitioners need to engage in ongoing efforts to recruit new members, maintain existing members, and respond to new requests. Community coalitions should remain involved and continue to monitor the community so that they are ready to take action as new issues of alcohol availability arise.
- Encourage communities to utilize practitioners. Prevention practitioners are an important source of information, guidance, and resources for community coalitions. When staff changes occur, it is important for new practitioners to introduce themselves to the community and work to establish a trusting relationship.
- Organize mindfully. The success of community coalitions depends on the participation and collaboration of local community groups, public agencies, and organizers. Grassroots community members in coalitions should have authority over the direction of the prevention efforts equal to that of service providers, city officials, and other professional participants. Some agencies and groups are good partners in certain coalitions but not in others, depending on the issues. For example, the police are good coalition partners for public safety issues. As public employees, however, their need to remain impartial would prohibit them from being coalition partners for other, more politicized, issues.
- Identify, secure, and organize data to document your case. In preparation for community coalition interventions, collect baseline data to demonstrate the relationship between outlet density and problems. In many cases, public agencies such as health and welfare departments, ABC's, police, and education departments have such data in public records. Pay special attention to finding innovative ways of visually presenting the information.