# What the Community Needs to Know to Manage Alcohol Problems

Communities that want to make an impact on the availability of alcohol need to understand how alcohol is sold (made available) in the community; the relationships between alcohol outlets and alcohol-related problems; and the systems for managing alcohol availability.

## How Alcohol Is Sold

Three forms of alcohol availability are of particular interest.

- Retail availability - Commercial availability. Dimensions of control include price, density of outlets, types of outlets, serving practices, hours and days of sale, and one-day and short-term licenses. The relationship between retail availability, consumption, and public health and safety problems is the primary focus of this practitioner's guide.
- Public availability - Public events and places. Public availability is usually controlled by local jurisdictions, but the State Alcohol Beverage Control (ABC) board may control availability at State-sponsored events or locations.
- Social availability - Social customs and traditions related to alcohol use. Social availability is the product of community history, beliefs, and cultures that shape the norms for drinking and social host practices at private events. (This type of availability is not a direct focus of this guide, but it does affect other forms of availability.)
- To make an impact on alcohol availability, practitioners and community leaders should have a common understanding of a few terms, the most important of which are defined below. A full glossary is provided in appendix B.
- Alcohol outlet - A place that sells alcoholic beverages to the public or a select membership. Outlets vary throughout the United States because of differences in State regulations and types of retail alcohol licenses. Licenses are issued to applicants to sell alcohol for consumption on, off, or both on and off their premises.
- Alcohol outlet capacity - The serving capacity of one outlet or of all outlets in a given area. On-sale capacity is calculated by the number of seats in the outlet or the outlet's square footage. Off-sale capacity is calculated by the number of linear feet of shelves devoted to alcohol sales or the outlet's square footage.
- Alcohol outlet density - The number of outlets licensed to sell alcohol within a given geographic area.
- On- or off-sale outlet - An on-sale outlet is licensed to sell alcohol for consumption within, but not outside of, its establishment. Examples include bars, taverns, clubs, and some restaurants. An off-sale outlet is licensed to sell alcohol for consumption outside of, but not within, its establishment. Examples include liquor stores, supermarkets, wine shops, gas stations, and minimarkets.

## Alcohol Outlets and Alcohol-Related Problems

Changes in alcohol control systems and in the availability of alcohol can have a significant impact on the patterns and problems of alcohol consumption. The key environmental factors that influence where, when, and how much people drink are types of regulations, enforcement practices, outlet density, hours and days of sale, and forms of retail outlet availability.

## Systems for Managing Alcohol Availability

Today, management of alcohol availability is based on a system of State ABC boards. State laws regarding the oversight of alcoholic beverages preempt those of cities and counties. However, since the late 1970's, the States have delegated varying degrees of power to local governments for retail licensing and local enforcement.

alcohol management - ways in which a State plays a role visà-vis the local authorities in controlling the distribution and marketing of alcohol.

The ways in which States approach alcohol management can be divided roughly into four categories: (1) Some States prohibit local control of alcohol availability and marketing in virtually all circumstances. They are called "control States." (2) Many States place primary authority at the State level but allow local control through zoning ordinances and local police enforcement of alcohol laws. (3) Some States provide concurrent State and local authority. (4) Many States give primary authority to local jurisdictions, with only limited State involvement. They are called "license States."

Most local jurisdictions do not fully use their powers to prevent problems related to alcohol availability. But this picture is changing as communities begin to recognize the negative impact alcohol outlets can have. Communities that might once have taken action only after problems arose are now taking action to prevent problems from arising.

Cities and counties are beginning to put "alcohol elements" into their master plans. They are also beginning to take stronger measures, such as these:

- Writing zoning ordinances specifically to manage retail alcohol outlets. These ordinances address such concerns as public decorum, litter, noise, traffic, loitering, harassment, sale of alcohol to minors, underage drinking, driving under the influence, alcohol-related crime and violence, and public inebriation.
- Imposing conditions on the sale and use of alcohol in public places and at public events.
- Setting policies regarding drinking at official public agencies' activities and functions.
- Enacting local ordinances (other than those tied to planning and zoning ordinances) specifying how far away alcohol outlets must be from churches and schools.