# Why Use Environmental Approaches?

The effective management of alcohol availability is a community problem. The more available alcohol is in the environment, the more likely it is that the community will have a higher alcohol consumption rate. A high alcohol consumption rate has been found to be related to an increased number of problems, such as the following:

- Automobile-related injuries and deaths - Alcohol is a factor in 41 percent of traffic fatalities. Alcohol-related car crashes are the number one killer of teens.
- Homicides, manslaughters, and suicides - Alcohol is a factor in more than 50 percent of homicides, 68 percent of manslaughters, and 33 percent of suicides.
- Head injuries - More than 50 percent of those who sustain head injuries are drinking alcohol when injured.
- Domestic accidents - Alcohol is a factor in 21 to 47 percent of drownings, 35 to 63 percent of deaths due to falls, and 12 to 61 percent of deaths due to fire.
- High costs - In 1990, alcohol-related problems cost the Nation $98.6 billion! That is a 40 percent rise between 1985 and 1990. Estimates for the total lifetime cost for an individual with a severe head injury are as high as $4.6 million.
- Unprotected sex - Teens who drink are less likely to use condoms or other methods to prevent pregnancy and sexually transmitted diseases.

These costly problems may strain community resources, including fire, police, and ambulance crews; emergency department personnel and facilities; and the court system. Therefore, prevention involves many community systems: health, education, transportation, law, engineering, architecture, and public safety. It takes the concerted effort of concerned citizens, community groups, businesses, and officials from local and State agencies to develop and implement effective strategies.

Although communities can largely manage these problems through State and local government entities, many do not.

Efforts that focus solely on individual problem drinkers or on individual outlets are not sufficient. Public health strategies must also prevent or reduce problems related to availability through local laws, policies, and programs. In practical terms, this means placing reasonable limitations on the retail distribution of alcohol, on the operation of alcohol outlets, and on the management of events at which alcohol is sold. This practitioner's guide describes six prevention approaches that focus on limiting the availability of alcohol in the community in order to help reduce alcohol-related problems.