# Appendix C: Background on PEPS

The Prevention Enhancement Protocols System (PEPS) is a process that synthesizes a body of knowledge on specific prevention topics. It was created by the Division of State and Community Systems Development of CSAP/SAMHSA primarily to support and strengthen the efforts of State and Territorial agencies responsible for substance abuse prevention activities. The PEPS program is CSAP's response to the field's need to know "what works" and is an acceptance of the responsibility for leading the field with current information supported by the best scientific knowledge available.

This third guide in the PEPS series summarizes state-of-the-art approaches and interventions designed to strengthen the role of communities in preventing substance abuse and other alcohol-related problems. This topic was chosen in response to the field's expressed need for direction and in recognition of the important role of the environment as the first line of defense against the dangerous, insidious, and addictive consequences of alcohol use.

## The PEPS Development Process

The development of a PEPS guide begins with the deliberations of a Planning Group of nationally known researchers and practitioners in the field of substance abuse prevention. With input from their colleagues in the field, these experts identify a topic area that meets preestablished criteria for developing a guide. A Federal Resource Panel (FRP) with representatives from appropriate Federal agencies then convenes to discuss the proposed content of the guide. The FRP, taking into consideration recommendations from CSAP and the PEPS Planning Group, identifies those experts in the field best suited to serve on an Expert Panel for the chosen topic.

The Expert Panel meets to determine the scope of the problem to be addressed in the guide. The PEPS staff conducts exhaustive searches for relevant research and practice information, guided by the knowledge of the Expert Panel and its chair. The studies and practice cases found are analyzed and their findings compiled and presented in draft form according to the similarity of the prevention approaches used.

A subpanel of selected Expert Panel members then meets to apply the PEPS Rules of Evidence (described later in this section) to formulate summary judgments on the quality of the research and practice evidence, by approach, and to develop recommendations for the prevention field. This draft is reviewed by the full panel. A revised version of the guide, including the revisions of the Expert Panel, is distributed for review by the field. The critiques and analyses received are used to further refine and increase the accuracy, readability, and presentation of the guide.

## PEPS Series Goals

The primary goal of PEPS is to develop a systematic and consistent process for improving substance abuse prevention practice and research. Its objectives are to

- Synthesize research and practice evidence on selected topics
- Present recommendations for effective substance abuse prevention strategies in versions suitable for several target audiences
- Ensure that PEPS products receive optimal dissemination among target audiences
- Monitor the usefulness and relevance of PEPS products

Although lessons from available science are distilled and specific recommendations are made, this guide is not a "how-to" handbook, nor is it a prescriptive prevention planning guide. Audiences for PEPS products include State prevention agencies, other Federal and State authorities, and community-based organizations addressing the problems of substance abuse or serving high-risk populations. Therefore, targeted users of the PEPS guides include policy analysts and decisionmakers, who need sound data to justify funding for prevention planning; State agency and community-based administrators and managers, who will find the series useful in allocating resources and planning programs; researchers, who will receive guidance on the need for future studies; and practitioners, who will find recommendations for programming options that are most appropriate for the populations they serve.