# Appendix B: Glossary

## Acronyms

ABC | Alcoholic Beverage Control (board or agency)
CSAP | Center for Substance Abuse Prevention
CUP | conditional use permit
DWI | driving while intoxicated
FRP | Federal Resource Panel
MADD | Mothers Against Drunk Driving
PEPS | Prevention Enhancement Protocols System
SAMHSA | Substance Abuse and Mental Health Services Administration

## Glossary

alcohol management - ways in which a State plays a role vis-á-vis the local authorities in controlling the distribution and marketing of alcohol.

alcohol outlet - a place that sells alcoholic beverages to the public or to a select membership for consumption on- or off-premises. See also off-sale outlet and on-sale outlet.

alcohol outlet capacity - measured in the aggregate for all outlets in a given area or for a single establishment. See also on-sale capacity and off-sale capacity.

alcohol outlet density - the number of alcohol outlets licensed to sell alcohol within a determined geographic area. See also geographic density.

availability - the means by which alcohol is made available at the community level. See public availability, retail availability, and social availability.

commercial density - the percentage of alcohol outlets in relation to the total number of other commercial (i.e., non-alcohol-related) outlets in a given planning area. See population density.

community - a group of individuals who share cultural and social experiences within a common geographic or political jurisdiction.

community-based approach - a prevention approach that relies on several interventions in concert, involving various sections of the community, drawing on multiple local resources to address a community problem. Programs that involve coordinated multiple interventions are likely to be more effective in achieving the desired goals than single-component programs and programs that involve multiple but uncoordinated interventions. See also single-component program.

community readiness - the degree of support for or resistance to identifying substance use and abuse as significant social problems in a community. Stages of community readiness for prevention provide an appropriate framework for understanding prevention readiness at the community and State levels.

conditional use permit - a permit that is granted pursuant to certain conditions allowing the sale or consumption of alcohol. It may be awarded on a temporary or permanent basis.

control state - a State that employs a control system of alcohol distribution. See license State and control system.

control system - a system in which the State distributes and sells retail alcoholic beverages. See also license system.

cross-sectional design - a research design that involves the collection of data on a sample of the population at a single point in time. When exposure and health status data are collected, measures of associations between them are easily computed. However, because health status and exposure are measured simultaneously, inferences cannot be made that the exposure causes the health status.

data - information collected according to a methodology using specific research methods and instruments.

data analysis - the process of examining systematically collected information.

design (often referred to as research or study design) - an outline of the procedures to be followed in scientific experimentation in order to reach valid conclusions. See also experimental design, nonexperimental design, quasi-experimental design.

documentation (monitoring) - entails keeping records, collecting data, and/or making observations in order to obtain specific kinds of information; for instance, the rates of alcohol-related problems, consumption, and sales.

effect - a result, impact, or outcome. In evaluation research, attributing an effect to a program or intervention requires establishing, through comparison, a logical relationship between conditions with and without the program or intervention.

evaluation - entails analyzing the data obtained through documentation in order to assess the operation or impact of the service, program, or procedure.

experimental design - a research design that includes random selection of study subjects, an intervention and a control group, random assignment to the groups, and measurements of both groups. Measurements are typically conducted before and always after the intervention. The results obtained from these studies typically yield the most interpretable, definitive, and defensible evidence of effectiveness.

fortified wine - a wine that has had alcohol, usually in the form of grape brandy, added to it either during or after fermentation.

geographic density - the density of alcohol outlets per land area for a given geographic area, such as a planning district, police reporting district, ZIP code, or census tract. See alcohol outlet density.

happy hour - a promotional activity, usually held during specific evening hours, in which bars and other on-site outlets provide alcoholic beverages at a reduced price.

high-risk outlet - a retail alcohol outlet that endangers the public health, safety, or well-being of the community. The outlet may conduct high-risk promotional activities or contribute to excessive noise, traffic, litter, loitering, or other problems. See also high-risk setting and problem outlet.

high-risk setting - denotes the location of alcohol outlets where the threat to the health, safety, or well-being of the community is escalated by other factors, such as high crime rates or dangerous highways. See also high-risk outlet.

institutionalization - occurs when a program is supported by the community and local or State governments and incorporated in routine operations. Although the program is accepted as a routine and valuable practice at this stage, there is little perceived need for change or expansion of the effort. See community readiness.

intervention - a manipulation applied to a group in order to change behavior. In substance abuse prevention, interventions at the individual or environmental level may be used to prevent or lower the rate of substance abuse or substance abuse-related problems.

lessons learned - in this guide, conclusions that can be reached about a specific prevention approach based on the research and practice evidence.

license state - a State that employs a license system of alcohol distribution. See also control State and license system.

license system - system in which the State licenses the private sector to distribute and sell retail alcoholic beverages. See also control system.

natural experiment - a change in a situation, policy, or process, typically not initiated by researchers but which can be evaluated. For example, the passage of a law that eliminates a State monopoly and permits private retail alcohol sales may occur for reasons unrelated to substance abuse prevention. However, researchers can evaluate the effect of this natural experiment on alcohol consumption and alcohol-related problems.

nonexperimental design - a type of research design that does not include random assignment or a control group. With such research designs, several factors prevent the attribution of an observed effect to the intervention.

off-sale capacity - the linear feet of shelves devoted to alcohol sales, or the square footage or floor space in a retail alcohol outlet. See also on-sale capacity.

off-sale outlet - a retail alcohol outlet licensed to sell alcohol for consumption outside of, and not in, the licensed establishment. See also alcohol outlet and on-sale outlet.

on-sale capacity - the number of seats in an on-sale outlet or the outlet's square footage. See also off-sale capacity.

on-sale outlet - a retail alcohol outlet licensed to sell alcohol for consumption within, but not outside of, the licensed establishment. See also alcohol outlet and off-sale outlet.

outcome evaluation - an analysis that focuses research questions on assessing the effects of interventions on intended outcomes. See process evaluation.

population density - in this guide, the concentration of retail alcohol outlets per population unit, or the number of outlets for a given population. See Commercial Density.

practice evidence - in this guide, information gained from prevention practice cases, generally compiled in the form of case studies, which often include process evaluation information on program implementation and procedures. See also research evidence.

pre- and post-tests - in research design, the collection of measurements before and after an intervention to assess its effects.

problem outlet - a retail alcohol outlet that resists cooperation with authorities or community groups in addressing high-risk practices or community complaints. See also high-risk outlet and high-risk setting.

process evaluation - an assessment designed to document and explain the dynamics of a new or continuing prevention program. Broadly, a process evaluation describes what happened as a program was started, implemented, and completed. A process evaluation is, by definition, descriptive and ongoing. It may be used to the degree to which prevention program procedures were conducted according to a written program plan. See outcome evaluation.

program evaluation - the application of scientific research methods to assess program concepts, implementation, and effectiveness. See also outcome evaluation and process evaluation.

public availability - availability of alcohol at public events and in public places. See also retail availability and social availability.

qualitative data - generally constitute contextual information in evaluation studies and usually describe participants and interventions. The strength of qualitative data that often are presented as text is their ability to illuminate evaluation findings derived from quantitative methods. See also quantitative data.

quantitative data - in evaluation studies, measures that capture changes in targeted outcomes (e.g., substance use) and intervening variables (e.g., attitudes toward substance use). The strength of quantitative data is their use in testing hypotheses and determining the strength and direction of effects. See qualitative data.

quasi-experimental design - a research design that includes intervention and comparison groups and measurements of both groups, but assignment to the intervention and comparison conditions is not done on a random basis. With such research designs, attribution of an observed effect to the intervention is less certain than with experimental designs.

questionnaire - research instrument that consists of written questions, each with a limited set of possible responses.

research - the systematic effort to discover or confirm facts by scientific methods of observation and experimentation.

research evidence - in this guide, information obtained from research studies conducted to evaluate the effectiveness of an intervention and typically published in peer-reviewed journals. The basis of this information is investigations whose designs range from experimental to quasi-experimental to nonexperimental. See also practice evidence.

retail availability - the commercial availability of alcohol. See also public availability and social availability.

single-component program - a prevention approach using a single intervention or strategy to target one or more problems. See also multicomponent program.

social availability - the social customs and traditions related to alcohol use. See also public availability and retail availability.

time-series design - a research design that involves an intervention group evaluated at least once before the intervention and more than once after the intervention. A time-series analysis involves the examination of fluctuations in the rates of a condition over a long period in relation to the rise and fall of a possible causative agent.

NOTE: This glossary is based partially on work performed by Westover Consultants, Silver Spring, Maryland, and the Pacific Institute for Research and Evaluation, Bethesda, Maryland, under other contracts with the Center for Substance Abuse Prevention.