# Appendix A: Resource Guide

This Resource Guide compiles recommended resources for practitioners who want to find out more about alcohol availability-related prevention approaches.

The first section lists names and addresses of researchers and practitioners whose work was considered as evidence in the evaluation of the research and practice evidence for the prevention approaches. They are listed under the approach they investigated. Because detailed descriptions of their program planning and content is beyond the scope of this guide (and often is not fully described in the published studies), CSAP felt that practitioners might want to obtain more detailed information directly from these sources.

The second section lists the various Federal Government agencies and nongovernment organizations that provide information, resources, and guidance regarding alcohol availability-related interventions and programs. Some of these have information clearinghouses.

## Researchers and Practitioners

### Approach 1: Preventing Availability to Underage Youth

- Jean L. Forster, Ph.D., M.P.H.
- School of Public Health
- Division of Epidemiology
- University of Minnesota
- 300 West Bank Office Building
- 1300 South Second Street, Suite 300
- Minneapolis, MN 55454-1015

- Ralph Hingson, Sc.D.
- School of Public Health
- Social and Behavioral Sciences Department
- Boston University
- 85 East Newton Street M840
- Boston, MA 02118

- Linda Mooney, Ph.D.
- Associate Professor
- Department of Sociology
- East Carolina University
- Greenville, NC 27858

- Patrick O'Malley, Ph.D.
- Senior Research Scientist
- Institute for Social Research
- University of Michigan
- 426 Thompson Street, Room 2311
- Ann Arbor, MI 48106-1248

- David Preusser
- Preusser Research Group
- 60 Oak Ridge Drive
- Bridgeport, CT 06611-2411

- Alexander Wagenaar, Ph.D.
- School of Public Health
- Division of Epidemiology
- University of Minnesota
- 1300 South Second Street, Suite 300
- Minneapolis, MN 55415-1015
- (612) 624-8370

### Approach 2: Raising Alcohol Taxes and Prices

- Thomas Babor, Ph.D., M.P.H.
- Department of Community Medicine
- University of Connecticut
- 263 Farmington Avenue
- Farmington, CT 06030-1910

- Sally Casswell, Ph.D.
- Alcohol and Public Health Research Unit
- Department of Community Health
- University of Auckland School of Medicine
- Private Bag 92019
- Auckland,New Zealand

- Douglas Coate, Ph.D.
- Professor
- Department of Economics
- Rutgers University
- 360 Martin Luther King, Jr.Boulevard
- Newark, NJ 07102

- Philip Cook, Ph.D.
- Sanford Institute of Public Policy
- Duke University
- 124 Sanford Institute Building
- Box 90239
- Durham, NC 27708-0239

- Paul Kohn, Ph.D.
- Department of Psychology
- Faculty of Arts
- York University
- 4700 Keele Street
- Toronto, Ontario, Canada M3J 1P3

- David Levy, Ph.D.
- Economics and Finance
- University of Baltimore
- 1420 North Charles
- Baltimore, MD 21201

- Henry Saffer, Ph.D.
- Kean College of New Jersey
- Research Associate
- National Bureau of Economic Research
- 50 East 42nd Street, 17th Floor
- New York, NY 10017-5405

- Reginald Smart, Ph.D.
- Social and Evaluation Research Department
- Addiction Research Foundation
- 33 Russell Street
- Toronto, Ontario, Canada M5S 2S1

### Approach 3: Responsible Beverage Service

- Ron Douglas, Ph.D.
- Community Programs and Services
- Addiction Research Foundation
- 33 Russell Street
- Toronto, Ontario, Canada P3C 1X3

- Scott Geller, Ph.D.
- Department of Psychology
- Virginia Polytechnic Institute and State University
- 5088 Derring Hall
- Blacksburg, VA 24061-0436

- Louis Gliksman, Ph.D.
- Social Evaluation and Research Department
- Addiction Research Foundation of Ontario
- The Gordon J. Mogenson Building
- 100 Collip Circle
- University of Western Ontario Research Park
- London, Ontario, Canada N6G 4X8

- Harold Holder, Ph.D.
- Director
- Pacific Institute for Research and Evaluation
- 2150 Shattuck Avenue, Suite 900
- Berkeley, CA 94704

- A. James McKnight, Ph.D.
- National Public Services Research Institute
- 8201 Corporate Drive, Suite 220
- Landover, MD 20785

- Martin Molof, Ph.D.
- Integrated Research Services, Inc.
- 66 Club Road
- Eugene, OR 97401

- James Mosher, J.D.
- The Marin Institute for the Prevention of Alcohol and Other Drug Problems
- 24 Belvedere Street
- San Rafael, CA 94901

- Alexander Wagenaar, Ph.D.
- School of Public Health
- Division of Epidemiology
- University of Minnesota
- 1300 South Second Street, Suite 300
- Minneapolis, MN 55415-1015
- (612) 624-8370

### Approach 4: Changing the Conditions of Availability

- Kaye Fillmore, Ph.D.
- Institute for Health and Aging
- 3333 California Street, Room 340
- San Francisco, CA 94118

- J.L. Fitzgerald, Ph.D.
- Department of Psychiatry
- Division of Alcohol Studies
- The University of Iowa
- Iowa City, IA 52242

- Paul Gruenewald, Ph.D.
- Prevention Research Center
- Pacific Institute for Research and Evaluation
- 2150 Shattuck Avenue, Suite 900
- Berkeley, CA 94704

- Harold Holder, Ph.D.
- Director
- Pacific Institute for Research and Evaluation
- 2150 Shattuck Avenue, Suite 900
- Berkeley, CA 94704

- David Lester, Ph.D.
- Center for the Study of Suicide
- RR41, 5 Stonegate Court
- Blackwood, NJ 08012-5356

- Scott Macdonald, Ph.D.
- Addiction Research Foundation
- University of Western Ontario
- 100 Collip Circle, Suite 200
- London, Ontario, Canada N6G 4X8

- David P. MacKinnon, Ph.D.
- Arizona State University
- Department of Psychology
- Tempe, AZ 85287-1104

- H.A. Mulford, Ph.D.
- Professor Emeritus
- Division of Alcohol Studies
- Department of Psychiatry
- College of Medicine
- University of Iowa
- Iowa City, IA 52242

- Sturla Nordlund
- National Institute for Alcohol and Drug Research
- Dannevigsveien 10
- 0463 Oslo, Norway
- (22) 38-04-85

- William Ponicki, M.A.
- Research Associate
- Prevention Research Center
- Pacific Institute for Research and Evaluation
- 2150 Shattuck Avenue, Suite 900
- Berkeley, CA 94704

- Richard Scribner, M.D., M.P.H.
- Assistant Professor of Public Health and Preventive Medicine
- Louisiana State University Medical Center
- 1600 Canal Street, Room 800
- New Orleans, LA 70116

- Reginald Smart, Ph.D.
- Social and Evaluation Research Department
- Addiction Research Foundation
- 33 Russell Street
- Toronto, Ontario, Canada M5S 2S1

- D. Ian Smith, Ph.D.
- Western Australian
- Alcohol and Drug Authority
- Construction House
- 35 Havelock Street
- West Perth, 6005, Australia

- Alexander Wagenaar, Ph.D.
- School of Public Health
- Division of Epidemiology
- University of Minnesota
- 1300 South Second Street, Suite 300
- Minneapolis, MN 55415-1015
- (612) 624-8370

- Friedner Wittman, Ph.D., M.Arch.
- President
- CLEW Associates
- 2198 Sixth Street
- Berkeley, CA 94710

### Approach 5: Changing Hours and Days of Sale

- William Hansen, Ph.D.
- Tanglewood Research, Inc.
- P.O. Box 1772
- Clemmons, NC 27012

- Ralph Hingson, Sc.D.
- School of Public Health
- Social and Behavioral Sciences Department
- Boston University
- 85 East Newton Street
- M840 Boston, MA 02118

- Mary Ann Pentz, Ph.D.
- Department of Preventive Medicine
- School of Medicine
- University of Southern California
- USC Norris Comprehensive Cancer Center
- 1441 Eastlake Avenue, MS-44
- Los Angeles, CA 90033-0800

### Approach 6: Community-Based Prevention Approaches

- Ron Douglas, Ph.D.
- Community Programs and Services
- Addiction Research Foundation
- 33 Russell Street
- Toronto, Ontario, Canada P3C 1X3

- Norman Giesbrecht, Ph.D.
- Prevention and Health Promotion Research and Development Department
- Addiction Research Foundation of Ontario
- 33 Russell Street
- Toronto, Ontario, Canada M5S 2S1

- Louis Gliksman, Ph.D.
- Social Evaluation and Research Department
- Addiction Research Foundation of Ontario
- The Gordon J. Mogenson Building
- 100 Collip Circle
- University of Western Ontario Research Park
- London, Ontario, Canada N6G 4X8

- William Ponicki, M.A.
- Research Associate
- Prevention Research Center
- Pacific Institute for Research and Evaluation
- 2150 Shattuck Avenue, Suite 900
- Berkeley, CA 94704

- David Preusser
- Preusser Research Group
- 60 Oak Ridge Drive
- Bridgeport, CT 06611-2411

- Robin Room, Ph.D.
- Research and Development Division
- Addiction Research Foundation of Ontario
- 33 Russell Street
- Toronto, Ontario, Canada M5S 2S1

- Henry Saffer, Ph.D.
- Kean College of New Jersey
- Research Associate
- National Bureau of Economic Research
- 50 East 42nd Street, 17th Floor
- New York, NY 10017-5405

- Richard Scribner, M.D., M.P.H.
- Assistant Professor of Public Health and Preventive Medicine
- Louisiana State University Medical Center
- 1600 Canal Street, Room 800
- New Orleans, LA 70116

- Reginald Smart, Ph.D.
- Social and Evaluation Research Department
- Addiction Research Foundation
- 33 Russell Street
- Toronto, Ontario, Canada M5S 2S1

- Alexander Wagenaar, Ph.D.
- School of Public Health
- Division of Epidemiology
- University of Minnesota
- 1300 South Second Street, Suite 300
- Minneapolis, MN 55415

- Hildebard Wette, Ph.D.
- Alcohol and Public Health Research Unit
- Department of Community Health
- Medical School University of Auckland
- Private Bag 92019
- Auckland, New Zealand

- Friedner Wittman, Ph.D., M.Arch.
- President
- CLEW Associates
- 2198 Sixth Street
- Berkeley, CA 94710

### Practitioners

- Association for Responsible Alcohol Control
- San Jose, CA

- Community Coalition for Substance Abuse Prevention and Treatment
- Los Angeles, CA

- Cops in Shops program
- Las Cruces, NM

- Donna Dossey
- Traffic Safety Bureau
- Transportation Programs Division
- New Mexico Highway and Transportation Department
- 604 West San Mateo
- Santa Fe, NM 87504-1149
- (505) 827-0427
- (800) 541-7952

- Escondido Community Alcohol Planning Project (ECAPP) of the Community Prevention Planning Demonstration Project
- Escondido, CA

- Manuel Espinoza
- California Alcohol Beverage Control
- 3810 Rosin Court, Suite 150
- Sacramento, CA 95834

- Lynne Krukosky
- Cape Assist
- Cape May County Council on Alcoholism and Drug Abuse
- 6 Moore Road
- Cape May Courthouse
- Cape May, NJ 08210

- Judy Sanders
- Community and Targeted Initiatives
- Housing and Community Development
- City of Portland, Oregon
- 808 Southwest Third Avenue, Suite 600
- Portland, OR 97204

- Steven Schmidt
- Pennsylvania Liquor Control Board
- Bureau of Alcohol Education
- Alcohol Education Program
- Room 602
- Northwest Office Building
- Harrisburg, PA 17124-0001

- Nick Teare
- Techniques for Effective Alcohol Management Coalition
- 7910 Woodmont Avenue, Suite 400
- Bethesda, MD 20814

- Dee Thomas
- Responsible Beverage Service Program Prevention Director
- Lincoln Council on Alcoholism and Drugs, Inc.
- 914 "L" Street, Suite A
- Lincoln, NE 68508

## Agencies, Organizations, and Foundations

### Government Agencies

- Bureau of Alcohol, Tobacco, and Firearms
- Distilled Spirits and Tobacco Branch
- 650 Massachusetts Avenue, NW
- Washington, DC 20226
- (202) 927-8140
- www.atf.treas.gov

- Center for Substance Abuse Prevention
- 5600 Fishers Lane
- Rockwall II, Suite 930
- Rockville, MD 20857
- (301) 443-0365
- www.health.org

- Division of Public Education and Dissemination
- Rockwall II, Eighth Floor
- 5600 Fishers Lane
- Rockville, MD 20857
- (301) 443-0373
- www.health.org

- National Clearinghouse for Alcohol and Drug Information (NCADI)
- P.O. Box 2345
- Rockville, MD 20847-2345
- (800) 729-6686
- www.health.org

- Centers for Disease Control and Prevention
- 1600 Clifton Road, NE
- Atlanta, GA 30333
- (404) 639-3311
- (770) 488-5705 (publication requests)
- www.cdc.gov/tobacco

- Department of Education
- Drug Planning and Outreach
- 400 Maryland Avenue, SW
- Washington, DC 20202
- (202) 260-3954

- Indian Health Service
- Division of Clinical and Preventive Services
- Alcoholism and Substance Abuse Programs
- 5600 Fishers Lane, Room 6820
- Rockville, MD 20857
- (301) 443-4297
- www.ihs.gov

- National Highway Traffic and Safety Administration
- Traffic Safety Programs
- Room 5118, NTS-11
- 400 Seventh Street, SW
- Washington, DC 20590
- (202) 366-9835

- National Institute on Alcohol Abuse and Alcoholism
- Prevention Research Branch
- Willco Building, Suite 505
- 6000 Executive Boulevard
- Rockville, MD 20892
- (301) 443-1677
- www.niaaa.nih.gov

- National Institute on Drug Abuse
- Division of Epidemiology and Prevention Research
- 5600 Fishers Lane, Room 9A-53
- Rockville, MD 20857
- (301) 443-1514
- www.nida.nih.gov

- National Transportation Safety Board
- 490 L'Enfant Plaza, SW
- Washington, DC 20594
- (202) 314-6000
- www.ntsb.gov

- United States General Accounting Office
- 441 G Street, NW
- Washington, DC 20548
- (202) 512-3000
- www.gao.gov

### Nongovernment Organizations

- Alcohol Research Group
- Medical Research Institute of San Francisco
- 2000 Hearst Avenue, Suite 300
- Berkeley, CA 94709-2176
- (510) 642-5208/fax
- (510) 642-7175
- www.arg.org

- Center for Prevention Research
- 1151 Red Mile Road, Suite 1A
- Lexington, KY 40504
- (606) 257-5588
- www.uky.edu/rgs/preventionresearch

- Center for Science in the Public Interest
- Alcohol Policies Project
- 1875 Connecticut Avenue, NW, Suite 300
- Washington, DC 20009
- (202) 332-9110
- www.cspinet.org

- Center of Alcohol Studies
- Rutgers University
- P.O. Box 969
- Piscataway, NJ 08855-0969
- (908) 445-2686
- www.rci.rutgers.edu/~cas2

- Community Anti-Drug Coalitions of America
- 901 North Pitt, Suite 300
- Alexandria, VA 22314
- (703) 706-0560/fax
- (703) 706-0565
- www.cadca.org

- Community Programs Department
- Addiction Research Foundation
- 888 Regent Street, Suite 302
- Sudbury, Ontario, Canada P3E 6E6
- (705) 675-1181
- www.arf.org

- Corporation for National and Community Service
- 1100 Vermont Avenue, NW
- Washington, DC 20525
- (202) 606-4806

- Corporation for National Service
- 1201 New York Avenue, NW
- Washington, DC 20525
- (202) 606-5000
- www.nationalservice.org

- Drug Abuse Prevention Research Center
- Center for the Study of Prevention Through Innovative Methodology
- Pennsylvania State University
- S. 159 Henderson Building
- University Park, PA 16802
- (814) 865-3253
- www.methcenter.psu.edu (scroll down to NIDA Center for the Study of Prevention Through Innovative Methodology)

- The Higher Education Center for Alcohol and Other Drug Prevention
- 55 Chapel Street
- Newton, Massachusetts 02158-1060
- (800) 676-1730
- www.edc.org

- Institute for the Study of Social Change
- Community Prevention Planning Project
- University of California, Berkeley
- 2232 Sixth Street
- Berkeley, CA 94710
- (510) 540-4717

- Insurance Institute for Highway Safety
- 1005 North Glebe Road, Suite 800
- Arlington, VA 22201
- (703) 247-1500
- www.hwysafety.org

- Join Together
- 441 Stuart St.
- Boston, MA 02116
- (617) 437-1500
- www.jointogether.org

- The Lindesmith Center
- 888 7th Ave., Suite 2700
- New York, NY 10106
- (212) 887-0695
- www.lindesmith.org

- The Marin Institute for the Prevention of Alcohol and Other Drug Problems
- 24 Belvedere Street
- San Rafael, CA 94901
- (415) 456-5692
- www.marininstitute.org

- Minority Adolescent Drug Use Prevention
- Social Psychology and Behavioral Medicine Research Group
- Department of Psychology
- University of Houston
- Houston, TX 77204-5341
- (713) 743-8555

- MultiEthnic Drug Abuse Prevention Research Center
- Cornell University Medical Center
- 411 East 69th Street, Room KB201
- New York, NY 10021
- (212) 746-1270
- www.lifeskillstraining.com

- National and Community Service Coalition
- 409 Third Street, SW
- Washington, DC 20024
- (202) 488-7378

- National Council on Alcoholism and Drug Dependence
- 12 West 21st Street
- New York, NY 10010
- (212) 206-6770
- www.ncadd.org

- Partnership for a Drug-Free America
- 405 Lexington Avenue
- New York, NY 10174
- (212) 922-1560
- www.drugfreeamerica.org

- Prevention Research Center
- 2150 Shattuck Avenue, Suite 900
- Berkeley, CA 94704
- (510) 486-1111

- Tri-Ethnic Center for Prevention Research
- Department of Psychology
- Colorado State University
- Clark Building, Room c-78
- Fort Collins, CO 80523
- (970) 491-7902

- Wisconsin Clearinghouse for Prevention Resources
- University Health Services
- University of Wisconsin-Madison
- 1552 University Avenue
- Madison, WI 53705
- (800) 322-1468
- www.uhs.wisc.edu/wch