# Reducing Tobacco Use Among Youth: Community-Based Approaches

This community guide is based on the recommendations of a panel of nongovernmental experts who systematically reviewed the current research on reducing tobacco use among youth. The Center for Substance Abuse Prevention, SAMHSA, offers these recommendations to communities in the hope that they will enhance local efforts to curb tobacco use by minors.

## We Should Be Concerned!

- Every day, 3,000 kids become regular smokers, and a third of them will eventually die of tobacco-related causes.
- Two out of three 12- to 17- year-olds who smoked cigarettes in the last year show signs of addiction.

Yet, despite these striking findings, only recently have we taken steps to protect our children. Maybe we just don't realize how serious the problem is.

## What Are the Facts?

Our young people are taking up smoking or chewing tobacco at a very early age-despite the fact that selling tobacco products to minors is illegal. The average age of first tobacco use is 12.2 years for children aged 12 to 17.

- 1 out of 2 eighth-graders has tried cigarettes.
- 1 out of 12 eighth-graders smokes cigarettes daily.
- If kids who use chewing tobacco are added, 42% of eighth-grade boys use tobacco regularly. By the time our boys are high school seniors, that figure rises to almost 50%!

## What Are the Consequences?

The use of tobacco by kids increases the likelihood of:

- Addiction
- Poor physical stamina
- More colds and lung infections
- Oral cancer

Smoking also gives the smoker foul breath, turns teeth yellow, and causes skin to wrinkle prematurely.

In addition, kids who use tobacco are more likely to:

- Use other drugs
- Engage in sex

FIGURE 1: Frequent Use of Cigarettes (1/2 pack or more per day), by Grade, 1991-1996

SOURCE: NIDA, NIDA Capsules: Monitoring the Future Study, 1975-1996, 1996.

The impact of adolescent tobacco use is serious. We must help our children stay away from tobacco.

## What Is Being Done?

Nationally, both the U.S. Department of Health and Human Services (DHHS) and the Food and Drug Administration (FDA) have taken steps that ban the sale of cigarettes and smokeless tobacco to minors. While the FDA's focus on the tobacco industry and retailers has resulted in limits on marketing and distribution aimed at protecting our youth, the DHHS has provided the financial incentive needed to make States comply.

Many research studies and community action programs have been launched by agencies, such as the Centers for Disease Control's Office of Smoking and Health, to test the effectiveness of prevention approaches.

The Center for Substance Abuse Prevention, at the DHHS, set up PEPS (the Prevention Enhancement Protocols System) to systematically sort out which prevention approaches work best. PEPS then developed guidelines for prevention practitioners and community members who are concerned about adolescent tobacco use.

## PEPS Recommends That You and Your Community

- Make prevention of adolescent tobacco use a high priority.
- Work to change local structures, policies, or regulations that support early tobacco use and abuse.
- Develop a broad base for community action. Include:

- Students and student organizations - Representatives of your school system - Parents and other concerned community members - Community leaders and other prominent individuals - Representatives of your community's ethnic groups - Community businesses, merchants, and organizations - Government agencies - Social agencies, associations, and tobacco control groups - The mayor's office - The police and the judicial system

- Build a partnership with health practitioners.
- Get involved and stay involved. Efforts must be continually renewed. Each year, more children and adolescents join the ranks of tobacco users.

FIGURE 2: Percentage of Youth Who Used Drugs in the Past Month, Smokers and Nonsmokers

NOTE: Numbers are extrapolations for the percentages to all youths represented by the 12- to 17-year-olds in the study sample.

SOURCE: SAMHSA, National Household Survey on Drug Abuse: Main Findings 1994, 1996.

## Are Some Programs Effective?

Yes! PEPS found that six approaches show the potential for success:

1. Economic Interventions-Raising the price of tobacco through taxes
2. Counteradvertising-Promoting a negative image of tobacco use
3. Retailer Interventions-Reducing youth access to tobacco products
4. Multicomponent, School-Based Interventions-Adding parent involvement, student activism, and media campaigns to school-based efforts
5. Policies for Tobacco-Free Environments-Creating smoke-free schools, recreation sites, and workplaces
6. Restrictions on Industry Advertising and Promotion-Eliminating tobacco industry sponsorship of sports and cultural events.

You can see at a glance that each of these interventions involves a lot of work. Many efforts. Many hands. You can find many sources of help:

- CSAP and other Federal agencies provide information on what works in prevention. (See list at end of document.)
- Your State health department provides funding, offers consultation, and coordinates prevention programs throughout the State.
- Local or county health departments provide professional staff and additional funds for local prevention programs.

But none of this support can be effective without your involvement.

- Get involved today.
- Talk to your neighbors and friends.
- Help build the strong, grassroots support necessary for success.

## What Can You Do?

Just about anything! Possible activities are so varied that there is bound to be something for everyone. For example, you might:

- Help conduct a survey to determine your community's readiness for action.
- Be part of a community prevention program planning team.
- Speak out. Convince your friends, neighbors, and work colleagues that tobacco use among minors is a high-priority problem.
- Encourage other members of your community to get involved.

Once your community develops its plan of action, you can:

- Promote increased taxes on tobacco products.
- Look for new sponsors to replace tobacco industry sponsorship of local sports and cultural events.
- Visit local retailers to explain the law against tobacco sales to minors.
- Attend school programs that help parents learn how to discourage tobacco use.
- Ask owners of cigarette vending machines to cooperate with community efforts to make tobacco products less accessible to youth.
- Urge judges to apply sanctions against retailers who sell tobacco products to minors.
- Convince school administrators to offer smoking-cessation programs for nicotine-dependent students.
- Work on media campaigns to support your community prevention program.

## What's Next?

The future of your local prevention effort begins right now.

- Attend planning meetings.
- Speak up. Ask questions. Express your concerns. Share ideas.
- Sign up. Put your name on the line. Let program organizers know about your special interests and talents.
- Share everything you learn with neighbors and friends.
- Talk with your own kids about the dangers of smoking cigarettes and using chewing tobacco.
- Encourage your kids to get involved in the community program.

## Success Is Possible. Be a Part of It!

Millions of adult Americans have stopped using tobacco. Smoking is increasingly viewed as a socially unacceptable practice, while being tobacco-free is seen as the norm. Many smokers and nonsmokers are becoming aware of the importance of smoke-free environments. Commercial flights are smoke-free. Many public buildings, offices, and restaurants are also clean-air environments.

The process has not been easy. But the changes are dramatic. Building on that success, we can create a tobacco-free future for our children. It won't just happen. But, together, we can make it happen.

## Sources for Information on Smoking and Health

### Government Sources

Agency for Health Care Policy and Research Publications Clearinghouse 1-800-358-9295 http://www.ahcpr.gov/

Center for Substance Abuse Prevention National Clearinghouse for Alcohol and Drug Information (301) 468-2600 1-800-Say-No-To http://www.health.org/

Centers for Disease Control and Prevention National Center for Chronic Disease Prevention and Health Promotion Office on Smoking and Health (770) 488-5705 (publication requests) 1-800-CDC-1311 (media campaign line) http://www.cdc.gov/tobacco/

Environmental Protection Agency Indoor Air Quality Information Clearinghouse (513) 569-7562 http://www.epa.gov/

Federal Trade Commission Public Reference Branch (202) 326-2222 (publications) (202) 326-3150 (tobacco-related questions)

Food and Drug Administration Office of Consumer Affairs (301) 443-3170 http://www.fda.gov/bbs/tobacinfo/juristoc.html

Indian Health Service Communications Staff (301) 443-3593

National Cancer Institute Office of Cancer Communications 1-800-4-CANCER http://www.nci.nih.gov/occdocs/occ.htm

National Center for Health Statistics Data Dissemination Branch (301) 436-8500 http://www.cdc.gov/nchswww/nchshome.htm

National Health Information Center Reducing Tobacco Use Among Youth 1-800-336-4797 (301) 565-4167 http://nhic-nt.health.org/

National Heart, Lung, and Blood Institute Information Center (301) 251-1222

National Institute for Occupational Safety and Health Technical Information Branch 1-800-35-NIOSH (513) 533-8326 http://www.cdc.gov/niosh/homepage.html

National Oral Health Information Clearinghouse (301) 402-7364 nidr@aerie.com

National Technical Information Service (703) 487-4650 1-800-553-NTIS

Occupational Safety and Health Administration Department of Labor (202) 219-8151 http://www.osha.gov/

Office of Minority Health Resource Center (800) 444-6472

United States Department of Agriculture Tobacco and Peanut Division (202) 720-4318

United States Department of Treasury Bureau of Alcohol, Tobacco, and Firearms Distilled Spirits and Tobacco Branch (202) 927-8210

### Nongovernment Sources

Action on Smoking and Health (202) 659-4310 http://ash.org/

The Advocacy Institute (202) 659-8475

American Association of Retired Persons Health Advocacy Service (202) 434-2300

American Cancer Society 1-800-ACS-2345 http://www.cancer.org/tobacco.html

American Council on Science and Health (212) 362-7044

American Heart Association National Center 1-800-AHA-USA1 http://www.amhrt.org/

American Lung Association (212) 315-8700 1-800-LUNG-USA http://www.lungusa.org/

American Medical Association (312) 464-5000 http://www.ama-assn.org

Americans for Nonsmokers' Rights (510) 841-3032 http://www.no-smoke.org/

Association of State and Territorial Health Officials (202) 546-5400

Coalition on Smoking OR Health (202) 452-1184

Doctors Ought to Care (713) 528-1487 http://www.bcm.tmc.edu/doc/

Group Against Smokers' Pollution (301) 459-4791

March of Dimes Birth Defects Foundation (914) 428-7100

National Federation TARGET Program (816) 464-5400

SmokeFree Educational Services, Inc. (212) 912-0960

Stop Teenage Addiction to Tobacco (413) 732-STAT

## Thank you for your interest! Together, we will make a tobacco-free future for our young people

For a printed version of this publication, please contact: National Clearinghouse for Drug and Alcohol Information (NCDAI) www.health.org 1-800-729-6686 (TDD 1-800-487-4889)