# Donor Registries for Bone Marrow Transplantation

Technology Assessment, May 13-15, 1985

## Introduction

The bone marrow produces the normal blood elements: red cells, white cells, and platelets. If the bone marrow ceases to function, as in aplastic anemia, or is replaced by abnormal cells, as in leukemia, then a bone marrow transplant from another individual may be useful.

The first phase of a bone marrow transplant is preparation of the recipient for the graft. Therapy to suppress the immune system is generally given in this phase. This is done to permit the recipient to accept the foreign bone marrow graft. Second, healthy marrow is taken from a tissue-matched brother or sister who shares certain genes with the patient, i.e., an HLA-identical sibling. The procedure is identical for unrelated donors. The collection of bone marrow from the normal donor involves the administration of general anesthesia and the insertion of a needle into the hip bone to withdraw marrow, usually from numerous sites. The marrow is then given by vein to the patient. The transfused marrow starts to function in 2 to 4 weeks. During this time, the patient is particularly vulnerable to infection.

After the grafted cells have started to multiply, the patient may develop graft-versus-host disease. Graft-versus-host disease occurs when the donor lymphocytes respond to antigens present on host (recipient) cells. The donor cells are activated and attack the host tissues, particularly the skin, intestinal tract, liver, and the immune system. Symptoms of acute graft-versus-host disease occur in 1 to 2 months and may include skin rash, diarrhea, jaundice, and increased susceptibility to infection. Acute graft-versus-host disease develops in 30 to 70 percent of patients transplanted with HLA-identical marrow and contributes to death in 20 to 40 percent of patients receiving a bone marrow transplant. Between 15 and 50 percent of transplanted patients who survive 6 months may develop chronic graft-versus-host disease with symptoms such as skin changes, joint contractures, and liver failure. The better the tissue matching between donor and recipient, the less the severity of graft-versus-host disease.

In the 1960's, it became possible to identify brothers and sisters who were compatible by tissue typing. This advance made it possible to perform a bone marrow transplant safely. With the experience accumulated since then, HLA-identical marrow transplantation has moved from being experimental therapy to being a major alternative treatment for certain disorders.

The largest number of patients receiving transplants have been those with leukemia. The intensive pretransplant therapy in these patients is designed to destroy malignant cells as well as to immunosuppress the recipient. Fifty to 80 percent of patients with acute myelogenous leukemia transplanted during their first remission from the disease show a prolonged disease-free survival. Patients with recurrent acute leukemia and chronic leukemia have also shown favorable responses. In addition, long-term remissions are seen in 40 to 80 percent of patients with aplastic anemia, and long-term survival of 55 percent has been reported in patients with severe combined immunodeficiency disease treated with bone marrow transplantation. Patients with genetic disorders of the bone marrow such as thalassemia major can also be helped in some instances with bone marrow transplantation. New applications for bone marrow transplantation are likely to develop in the future, while some current indications may change.

The above results have been gathered predominantly in bone marrow transplantation between HLA-identical siblings; however, only about one-third of patients for whom a transplant may be indicated will have an HLA-identical sibling donor. For this reason, there is interest in identifying other donors. Improved knowledge of tissue typing and new methods to combat graft-versus-host disease that are under investigation have allowed physicians to consider both partially matched family members and matched unrelated individuals as possible marrow donors.

In late l984, Congress passed legislation directing the Secretary of Health and Human Services to convene a technology assessment conference to explore the feasibility and efficacy of setting up a national registry of individuals who could donate marrow to unrelated patients. Secondary charges were to evaluate whether a permanent registry was needed and appropriate and to study the issues involved in the establishment and implementation of the registry.

There are four questions that will be directly addressed in this report:

1. What is the experience with the possible alternatives to HLA-identical siblings as bone marrow donors for transplantation? Are these alternatives comparable?
2. Should a national bone marrow donor registry be established?
3. To what extent could the existing registries/blood donor programs be utilized as a source of potential unrelated bone marrow donors? What would be the impact on these programs?
4. What are the logistic, legal, and ethical issues involved in establishing registries of unrelated donors? To what risks are donors exposed?

## What Is the Experience with the Possible Alternatives to HLA-Identical Siblings as Bone Marrow Donors for Transplantation? Are These Alternatives Comparable?

The largest experience in marrow transplantation is with HLA-identical sibling donors. However, since only one-third of patients have an HLA- identical sibling, alternative donor sources are being used with increasing frequency. The alternative sources of marrow currently available are autologous (i.e., one's own marrow), partially matched family member donors, and unrelated donors. The experience to date with these various methods is limited, and all of these alternative sources are under continuing development.

Autologous marrow transplantation is being evaluated in a number of centers for patients with leukemia, lymphoma, and solid tumors. The major advantage of autologous marrow transplantation is lack of graft- versus-host disease. Autologous marrow transplantation is not possible for patients with immune deficiency, genetic disorders, severe aplastic anemia, or for patients who have marrow replaced by tumor.

When an HLA-identical sibling is not available, partially matched family members have been used as donors. The patients who have the best matched donors have had the best outcome. Specifically, patients with leukemia mismatched with the donor for only one HLA antigen have outcomes similar to those receiving transplants from HLA-identical siblings. Less than 10 percent of patients have this type of match with a family member.

Most patients have a family member who is a potential donor and who is haploidentical, i.e., shares one of two HLA chromosomes. Although a number of patients have been treated successfully using such donors, experience indicates an increased risk of graft-versus-host disease and graft rejection when results are compared with transplants between HLA- identical siblings. One approach that is under development for the reduction of graft-versus-host disease is depletion of immune cells from donor marrow. This procedure has given encouraging results. However, the risk of graft rejection appears to be increased over that seen in patients who receive untreated marrow. The followup of these patients is relatively short.

Bone marrow transplantation using unrelated donors has now been performed for immune deficiency diseases, severe aplastic anemia, and leukemia. Most patients with leukemia have had advanced disease. Most of the compatible donors were found through searches of local donor registries of HLA-typed individuals. To date, fewer than 70 such patients have been transplanted.

Recipients of unrelated donor marrow have generally experienced more problems with acute and chronic graft-versus-host disease than have recipients of HLA-identical sibling marrow. About 20 percent of recipients of unrelated marrow are alive and free of their disease for at least 3 months since transplantation. The longest living survivor was transplanted 3-1/2 years ago. Thus, survival in these patients has been poor, but not unlike the early experience with the use of HLA- identical donors in marrow transplantation for patients with advanced disease. Continuing efforts with the use of unrelated donors are certainly warranted.

The donor of choice for a patient with leukemia who lacks an HLA- identical sibling donor is a family member mismatched for not more than one HLA antigen. For other diseases, or if no such donor is available, the current results demonstrate no significant differences in survival with the use of unrelated matched marrow or haploidentical marrow from a family member. Both of these alternatives deserve further comparative studies, as does the use of autologous marrow transplantation.

## Should a National Bone Marrow Donor Registry Be Established?

Based on the developmental nature of bone marrow transplantation from unrelated donors and the limited information relating to the efficacy of this procedure, we have concluded that a centralized national registry for unrelated marrow transplant donors should not be established at this time. However, the modest success of the results obtained with matched unrelated donors does warrant continuation of this form of marrow transplantation and facilitation of the efforts of local donor registries. These local donor registries should be encouraged to continue and to expand their activities. A mechanism should be established to enable registries to communicate more effectively with each other and with transplant centers to assure that patients who are suitable candidates will have the best possible opportunity to receive bone marrow from an unrelated donor.

We propose an interim measure to be evaluated for its effectiveness in not more than 3 years. Specifically, we conclude that a coordinating center should be established to carry out the following functions:

1. Identify all existing registries and marrow transplant programs in the United States that are capable of participating in an unrelated donor marrow program.
2. Encourage international cooperation among registries.
3. Disseminate information about unrelated bone marrow transplantation to the general public, patients, physicians, transplant centers, and those maintaining or interested in maintaining local donor registries.
4. Facilitate the establishment of a communication network among local centers with the following functions: a. Respond to requests from individual patients and potential donors for information about unrelated bone marrow transplantation. The role of public education is particularly important in the case of bone marrow transplantation from unrelated donors because it is in a developmental stage. Questions of a clinical nature will be referred to the patient's physician. b. Respond to requests from transplant centers that have patients for whom they would like to locate a matched unrelated donor. c. Refer these requests to local transplant registries that have indicated interest in matching donors for specific patients. These registries, themselves, should determine whether they have a potentially matched donor and, if so, should communicate this fact directly to the transplant center working with the patient. The registry and transplant center should work together to arrange a transplant for the patient where feasible.
5. Gather data on the overall level of activity in unrelated bone marrow transplantation and the size and number of participating local registries.
6. Deal with other issues relevant to unrelated bone marrow transplantation such as medical, life, and disability insurance for donors, and legal considerations.

Funds will be required to support the education, coordination, and evaluation functions of the coordinating center. Unrelated bone marrow transplantation in the United States and its effect in relation to degree of donor-recipient matching, disease state, and other relevant variables should be monitored and data analyzed. These analyses should be reviewed at regular intervals of not more than 3 years by an independent panel of appropriate experts appointed by the Secretary of Health and Human Services. Studies of the effect of the procedures on unrelated bone marrow donors should also be undertaken and similarly evaluated. These investigations should be independent of the coordinating center, and reports should be prepared on a timely basis to enable the transplantation community to make a judgment on the effectiveness of this treatment.

## To What Extent Could the Existing Registries/Blood Donor Programs Be Utilized as a Source of Potential Unrelated Bone Marrow Donors? What Would Be the Impact on These Programs?

At present, there are approximately 100,000 people in the United States who are HLA typed for the purpose of providing blood components for transfusion. Of these, several thousand have consented to consider providing bone marrow for transplantation, if needed. The remainder have not been asked if they would be willing, but experience suggests that some 70 percent would consent if they were asked. This represents a significant resource for the bone marrow transplant donor program and could become the foundation of a national donor pool. With a typed donor pool of only 10,000 individuals, HLA A,B,DR identical and MLC compatible donors can be found for about 10 percent of recipients; a six-antigen (HLA A,B,DR) match could be achieved for 30 percent and a good partial match (DR identical, AB 3/4 antigens) for 80 percent of recipients. These calculations are based on data for Caucasians. The collection of similar data for other racial and ethnic groups is being made and should be intensified. Further, the enlargement of donor pools of other ethnic groups is needed and should be encouraged.

At this time, we see no useful purpose to be served by merging the data bases of individual donor programs into a single national data base. In fact, such a merger could be counterproductive. The degree of cooperation to be anticipated from donor centers is heavily dependent on a sense of local responsibility and community involvement. Donation of bone marrow is highly dependent upon a spirit of voluntarism and altruism. Maintaining the registries on a local level leaves unaffected currently operating relationships between donor centers and transplant services.

The goal of making unrelated bone marrow donors available throughout the country can be achieved with local registries by establishing a coordinating center to interact with donor centers, transplant services, local physicians, and patients. We urge the registries to encourage their existing panel of HLA-typed people to volunteer to participate as bone marrow donors. In addition, current HLA A,B typings should be expanded to include DR, DQ, and, if feasible, DP. This will shorten the time required for complete identification of an appropriate unrelated marrow donor. For some centers, this elapsed time is now on the order of months, and a significant fraction of potential recipients die while awaiting transplant. We believe the impact of this proposal on existing programs will be positive.

## What Are the Logistical, Legal, and Ethical Issues Involved in Establishing Registries of Unrelated Donors? to What Risks Are Donors Exposed?

Local bone marrow donor registries already in place have instituted a system unique in the level of sacrifice asked of living individuals to benefit a stranger. Life-threatening complications for all marrow donors have been rare; there were 13 reported in 4,800 analyzed marrow donations; however, a fatal complication could occur. Short-term discomfort appears manageable, and almost all donors are back to their usual activities within a week. Neither the psychological risks or benefits to the donor nor the long-term physical effects of donation have been studied.

Given the unprecedented and serious nature of this new social experiment, ethical, logistic, and social issues should be given careful thought and investigation. Every effort should be made to protect the donor and the recipient and to minimize logistical difficulty; careful scientific investigation and evaluation of the procedure should accompany the venture.

## Recommendations Involving Donors

### Eligibility for Registration

Only persons at least 18 years old who are capable of giving informed consent should be admitted into the registries for the purpose of serving as donors in unrelated transplants.

### Eligibility for Donation

At the point that donation is a real possibility, physical, laboratory, and psychological screening of the donor should be part of the process, to exclude individuals at particular risk.

### Informed Consent

The panel suggests a staged informed consent procedure that is active rather than passive. The donor should specifically agree to participate in a registry for bone marrow donors. Informed consent should be obtained in two or more stages: (1) a generalized consent to be listed as a potential donor of bone marrow and (2) a specific consent to be a donor for a particular recipient.

The donor consent process should be voluntary and uncoerced, and the donor should be provided with a full factual basis for decisionmaking, including complete available information on physical and other risks to himself or herself. The actual and possible financial consequences should be outlined as well as the scope of protection provided. The donor should be advised that the effectiveness of the procedure has not been fully evaluated. He or she should also be made aware of the procedure's possible contribution to medical knowledge.

The donor should be permitted a sufficient time period to reflect upon and consider the decision to donate marrow. During this time, counseling and the services of a donor advocate should be available.

The donor should be made aware that last minute withdrawal of consent to a transplant donation could be catastrophic to the patient. The donor ought not to withdraw from the transplant after the time at which the recipient's marrow has been destroyed in preparation for receipt of the donated marrow.

Evidence suggests that involvement of the donor's spouse in the decisionmaking at all points will decrease the risk of a late withdrawal by the donor.

### Quality Control

The donor should be assured that the marrow is collected under proper conditions and that it will be viable and used for an appropriate recipient in a situation where further knowledge about bone marrow transplantation will be accrued. Centers that collect bone marrow and centers that perform bone marrow transplants should have to meet certain standards, including substantial experience with the techniques in humans.

### Confidentiality

Registries must protect the confidentiality of donor information by utilizing a method such as coded identification. Only authorized registry personnel should have access to names and other identifying information. Statutory safeguards should be created at the Federal level to prevent unauthorized disclosure of data that will identify the individuals involved.

## Other Issues

### Donor Advocacy

To protect the donor's rights and interests, we recommend that a donor advocate be assigned by the relevant registry to the donor when a match is found. The role of the advocate will be to ensure that the consent is made without time pressure and with full information, to enhance the personal attention given to the donor during all procedures, to help prevent unnecessary inefficiencies and discomfort, to mobilize official expressions of gratitude after the donation, and to aid in the resolution of subsequent problems.

### Separation of Roles

It is strongly recommended that the person soliciting consent, the person screening the donor, and/or the donor advocate be separate from the health care providers involved in the direct care of the potential bone marrow recipient.

### Anonymity

Both positive and negative experiences have been reported as a result of contact between donor and recipient. To prevent undue pressure on the donor, we recommend that anonymity be preserved at least until after the donation. In any case, both recipient and donor should agree to any breach of anonymity.

## Recommendations Involving Recipients

### Informed Consent

Potential recipients of transplants should be presented with accurate data on the uncertainties at present in the use of unrelated donors, contrasted with the alternative therapies available. They should be advised that the search for a living unrelated donor is costly in terms of money and effort and should be initiated only for appropriate transplant candidates. Informed consent should be obtained before the search for a donor is initiated.

### Equitable Access

There are great inconsistencies in current coverage of bone marrow transplantation, both in regard to private insurance carriers and Federal and state reimbursement programs. In such a system, financially less well-off people are frequently excluded from access to registry searches and to the procedure. These inequities should be addressed.

## Research and Evaluation

The panel has already emphasized the importance of clinical trials and prospective medical studies of unrelated bone marrow donor transplants. In terms of evaluating the marrow transplant for the recipient, quality of life should be considered in addition to survival and disease status.

Because this is an experiment in social altruism, research about the donor should address social scientific and ethical questions. Donors' social-psychological states and attitudes both before and after donation should be investigated. Studies should be rigorously designed and should involve researchers who are independent of bone marrow registries and transplant programs.

## Conclusion

The establishment of the field of bone marrow transplantation in man has led to important therapeutic results. In some cases, patients for whom no other effective type of treatment exists can be cured by bone marrow transplantation. These encouraging results have been achieved primarily using HLA-identical sibling donors. However, only one-third of patients will have an HLA-identical sibling donor.

The desire to use bone marrow transplantation for patients who do not have an HLA-identical sibling donor has led to the evaluation of the use of unrelated bone marrow donors who have been matched with the recipient for HLA. Since the probability of finding HLA matches in unrelated individuals is low, large volunteer donor panels have been established in several locations. These local registries have identified over 100 potential matched unrelated donors, and almost 70 patients have been transplanted. About 20 percent of patients have survived for 3 months after transplantation, and one is still alive 3-1/2 years after transplant. Thus, at the present time, bone marrow transplantation from matched unrelated donors requires further evaluation.

Based on the limited information available on the efficacy of using matched, unrelated donors, we do not recommend that a national registry for unrelated donors should be established. There is already a large pool of several thousand typed potential donors in several local registries. We conclude that the most efficacious and reasonable development of this proposed use of unrelated donors for bone marrow transplantation, at the present time, is to promote and expand the functioning of these local registries.

In reaching our conclusions, we have taken into consideration the legitimate and persuasive need of patients for information about, and ready access to, bone marrow transplantation; the existence of local donor registries throughout the United States that have proven capability and that have considered most carefully the rights of donors and the preservation of those rights; and the need for further information regarding the usefulness of bone marrow transplantation using unrelated, HLA-matched donors. To this end, we urge the establishment of a coordinating center, which should function as a clearinghouse, to facilitate and speed access of patients to potential unrelated donors in local registries. The feasibility of transplants with unrelated marrow donors and the effects on both donor and recipient should be evaluated in the next several years to determine if a different organizational approach should be taken in the future.

## Technology Assessment Panel

- Brigid G. Leventhal, M.D.
- Panel Chairperson
- Special Assistant to the Associate Director
- Division of Cancer Treatment
- National Cancer Institute
- National Institutes of Health, Bethesda, Maryland

- Richard H. Aster, M.D.
- President,
- The Blood Center of Southeastern Wisconsin
- Clinical Professor of Medicine and Pathology
- Medical College of Wisconsin
- Milwaukee, Wisconsin

- Fritz H. Bach, M.D.
- Harry Kay Chair Professor of Immunobiology
- University of Minnesota
- Minneapolis, Minnesota

- William R. Berry
- Director
- Office of Organ Transplantation
- Health Resources and Services Administration
- U.S. Public Health Service
- Department of Health and Human Services
- Rockville, Maryland

- M. Julian Duttera, M.D.
- Director
- Enoch Calloway Cancer Clinic
- LaGrange, Georgia

- Seymour Grufferman, M.D., Dr.P.H.
- Associate Professor and Chief
- Division of Clinical Epidemiology
- Department of Pediatrics
- Director
- Cancer Prevention and Control Program
- Duke University Medical Center
- Durham, North Carolina

- Geoffrey P. Herzig, M.D.
- Associate Professor of Medicine
- Director of Bone Marrow Transplantation
- Washington University
- St. Louis, Missouri

- Ernst R. Jaffe, M.D.
- Distinguished University Professor of Medicine And Senior Associate Dean
- Albert Einstein College of Medicine
- Bronx, New York

- John H. Kersey, M.D.
- Professor of Pediatrics and Laboratory Medicine/Pathology
- Director
- Bone Marrow Transplantation Program
- University of Minnesota
- Minneapolis, Minnesota

- Jeffrey P. Krischer, Ph.D.
- Pediatric Oncology Group Statistical Office
- Professor and Chief
- Division of Epidemiology and Biostatistics
- Department of Pediatrics
- University of Florida College of Medicine
- Gainesville, Florida

- Grace Powers Monaco, J.D.
- President
- The Candlelighters Childhood Cancer Foundation
- Partner
- Law Firm of White, Fine, and Verville
- Washington, D.C.

- Herbert A. Perkins, M.D.
- Scientific Director
- Irwin Memorial Blood Bank of the San Francisco Medical Society
- San Francisco, California

- Stuart O. Schweitzer, Ph.D.
- Professor
- School of Public Health
- University of California, Los Angeles
- Los Angeles, California

- Roberta G. Simmons, Ph.D.
- Professor of Sociology and Psychiatry
- University of Minnesota
- Minneapolis, Minnesota

- LeRoy Walters, Ph.D.
- Director
- Center for Bioethics
- Kennedy Institute of Ethics
- Georgetown University
- Washington, D.C.

- Jack E. White, M.D.
- Director
- Howard University Cancer Center
- Washington, D.C.

## Speakers

- Patrick G. Beatty, M.D., Ph.D.
- "The Seattle Experience With Matched Unrelated Donors"
- Assistant Professor
- University of Washington
- Associate Director
- Histocompatibility Laboratory
- Puget Sound Blood Center
- Associate Member
- Fred Hutchinson Cancer Research Center
- Seattle, Washington

- Mortimer M. Bortin, M.D.
- "Low Risk of a Major Complication to Donors of Bone Marrow"
- Professor of Medicine and Scientific Director
- International Bone Marrow Transplant Registry
- Medical College of Wisconsin
- Milwaukee, Wisconsin

- Hayden G. Braine, M.D.
- "Other Implementation and Strategic Issues"
- Associate Professor of Oncology and Medicine
- Johns Hopkins Oncology Center
- Johns Hopkins University School of Medicine
- Baltimore, Maryland

- Bruce M. Camitta, M.D.
- "Bone Marrow Transplantation Using Fully Histocompatible Unrelated Donors"
- Professor
- Pediatric Hematology/Oncology
- Director
- Midwest Children's Cancer Center
- Medical College of Wisconsin
- Milwaukee Children's Hospital
- Milwaukee, Wisconsin

- Robert Peter Gale, M.D., Ph.D.
- "Bone Marrow Transplantation: Current Results With HLA-Identical and
- Sibling Transplants"
- Associate Professor of Medicine
- University of California, Los Angeles School of Medicine
- Los Angeles, California

- Roger D. Gingrich, M.D., Ph.D.
- "Partial Mismatching of the Unrelated Bone Marrow Donor in Clinical
- Transplantation: A Study of the Feasibility and Effectiveness"
- Director
- Bone Marrow Transplant Program
- Department of Internal Medicine
- University of Iowa College of Medicine
- Iowa City, Iowa

- Nancy E. Goeken, Ph.D.
- "Establishment and Utilization of an Unrelated Bone Marrow Donor
- Registry at the University of Iowa"
- Director
- Tissue Typing Laboratory
- Assistant Professor
- Department of Internal Medicine
- Veterans Administration and University of Iowa Medical Center
- Iowa City, Iowa

- E.C. Gordon-Smith, F.R.C.P.
- "T-Lymphocyte Depletion of Donor Bone Marrow in Human Bone Marrow
- Transplantation"
- Reader in Hematology
- Royal Post Graduate Medical School
- Consultant Hematologist
- Department of Hematology
- Hammersmith Hospital
- London, England

- John A. Hansen, M.D.
- "The Seattle Experience With Partially Matched Related Donors"
- Professor of Medicine
- University of Washington
- Director
- Histocompatibility Laboratory
- Puget Sound Blood Center
- Member
- Fred Hutchinson Cancer Research Center
- Seattle, Washington

- Jill M. Hows, M.D.
- "Unrelated Donor Transplants for Aplastic Anemia"
- Senior Lecturer in Hematology
- Royal Post Graduate Medical School
- Consultant Hematologist
- Department of Hematology
- Hammersmith Hospital
- London, England

- David C.O. James, M.D.
- "Experience of the Anthony Nolan Registry"
- Medical Director
- Anthony Nolan Laboratories
- St. Mary Abbots Hospital
- London, England

- Guido Lucarelli, M.D.
- "Bone Marrow Transplantation in Thalassemia"
- Chief of Hematology
- Department of Hematology
- Hospital of Pesaro
- Pesaro, Italy

- Jeffrey McCullough, M.D.
- "Experience of the St. Paul Regional Red Cross Bone Marrow Donor Registry"
- Professor
- Department of Laboratory Medicine and Pathology
- Director, Blood Bank
- University of Minnesota Hospitals
- Minneapolis, Minnesota

- Margaret C. McElligott, S.B.B.
- "Experience of the Blood Center of Southeastern Wisconsin in Recruiting
- Unrelated Bone Marrow Donors"
- Supervisor
- Special Patient Services
- Blood Center of Southeastern Wisconsin
- Milwaukee, Wisconsin

- Anthony J. Melaragno, C.D.R., M.C., U.S.N., M.D.
- "Alternative Sources of Transplantable Stem Cells: Cryopreserved
- Peripheral Blood Stem Cells and Human Cadaveric Bone Marrow"
- Research Medical Officer
- Transplantation Research Program Center
- Naval Medical Research Institute
- Bethesda, Maryland

- M. Ray Mickey, Ph.D.
- "Donor Pool Size for Bone Marrow Transplantation"
- Department of Biomathematics
- University of California, Los Angeles
- Los Angeles, California

- Richard J. O'Reilly, M.D.
- "Summary of Matched Unrelated Donor Experiences (single cases)"
- Chief
- Bone Marrow Transplantation Service
- Memorial Sloan-Kettering Cancer Center
- New York, New York 10021

- Glenn E. Rodey, M.D.
- "Impact of a Bone Marrow Donor Registry on Existing Blood Donor Systems"
- Professor of Medicine and Pathology
- Chief, Immunogenetics Services
- Washington University School of Medicine
- American Red Cross Blood Services, Missouri-Illinois Region
- St. Louis, Missouri 63110

- George W. Santos, M.D.
- "Discussion of Relative Merits of Alternatives to HLA-Identical Sibling
- Transplants"
- Professor of Oncology and Medicine
- Johns Hopkins University School of Medicine
- Baltimore, Maryland

- Mark Siegler, M.D.
- "Unique Ethical Issues Related to Bone Marrow Transplantation"
- Associate Professor and Director
- Center for Clinical Medical Ethics
- Acting Chief
- Section of General Internal Medicine
- Department of Medicine
- University of Chicago
- Chicago, Illinois

## Planning Committee

- Itzhak Jacoby, Ph.D. (Chairman)
- Acting Director
- Office of Medical Applications of Research
- National Institutes of Health
- Bethesda, Maryland

- Anne P. Ball, Ph.D.
- Chief
- Blood Diseases Branch
- Division of Blood Diseases and Resources
- National Heart, Lung, and Blood Institute
- National Institutes of Health
- Bethesda, Maryland

- Bruce D. Cheson, M.D.
- Cancer Expert for the Clinical Investigations Branch
- National Cancer Institute
- National Institutes of Health
- Bethesda, Maryland

- Gregory Curt, M.D.
- Deputy Director
- Division of Cancer Treatment
- National Cancer Institute
- National Institutes of Health
- Bethesda, Maryland

- Donald Denny
- Director of Organ Procurement
- Pittsburgh Transplant Foundation
- Pittsburgh, Pennsylvania

- Jerry Elliott
- Program Analyst
- Office of Medical Applications of Research
- National Institutes of Health
- Bethesda, Maryland

- Robert Peter Gale, M.D., Ph.D.
- Associate Professor of Medicine
- University of California, Los Angeles School of Medicine
- Los Angeles, California

- John A. Hansen, M.D.
- Professor of Medicine
- University of Washington
- Director
- Histocompatibility Laboratory
- Puget Sound Blood Center
- Member
- Fred Hutchinson Cancer Research Center
- Seattle, Washington

- Brigid G. Leventhal, M.D.
- Special Assistant to the Associate Director
- Division of Cancer Treatment
- National Cancer Institute
- National Institutes of Health
- Bethesda, Maryland

- Jeffrey McCullough, M.D.
- Professor
- Department of Laboratory Medicine and Pathology
- Director, Blood Bank
- University of Minnesota Hospitals
- Minneapolis, Minnesota

- Jane S. Schultz, Ph.D.
- Chief
- Genetics and Transplantation Biology Branch
- National Institute of Allergy and Infectious Diseases
- National Institutes of Health
- Bethesda, Maryland

- Michael J. Bernstein
- Director of Communications
- Office of Medical Applications of Research
- National Institutes of Health
- Bethesda, Maryland

## Conference Sponsors

- National Institute of Allergy and Infectious Diseases
- Anthony S. Fauci, M.D.
- Director

- National Heart, Lung, and Blood Institute
- Claude Lenfant, M.D.
- Director

- National Cancer Institute
- Vincent T. DeVita, Jr., M.D.
- Director

- Office of Medical Applications of Research, NIH
- Itzhak Jacoby, Ph.D.
- Acting Director

## About the NIH Technology Assessment Program

NIH Technology Assessment Conferences and Workshops are convened to evaluate available scientific information related to a biomedical technology when topic selection criteria for a Consensus Development Conference are not met. The resultant NIH Technology Assessment Statements are intended to advance understanding of the technology or issue in question and to be useful to health professionals and the public.

Some Technology Assessment Conferences and Workshops adhere to the Consensus Development Conference format because the process is altogether appropriate for evaluating highly controversial, publicized, or politicized issues. Other Conferences and Workshops are organized around unique formats. In this format, NIH Technology Assessment Statements are prepared by a nonadvocate, nonfederal panel of experts, based on: (1) presentations by investigators working in areas relevant to the consensus questions typically during a 1-1/2-day public session; (2) questions and statements from conference attendees during open discussion periods that are part of the public session; and (3) closed deliberations by the panel during the remainder of the second day and morning of the third. This statement is an independent report of the panel and is not a policy statement of the NIH or the Federal Government.

Preparation and distribution of these reports are the responsibility of the Office of Medical Applications of Research, National Institutes of Health, Federal Building, Room 618, Bethesda, MD 20892.