# Neurofibromatosis

National Institutes of Health Consensus Development Conference Statement, July 13-15, 1987

## Introduction

The neurofibromatoses are genetic disorders that primarily affect cell growth of neural tissues. These disorders can cause tumors to grow on the nerves at any location and at any time. Some manifestations are progressive and may result in significant morbidity or mortality. Two distinctive forms are recognized, but variant forms may exist. A variety of names have been used to describe all forms; subsequent information has made these names technically inaccurate or incomplete. To avoid these historical legacies and to conform to current nosology in other diseases, the Consensus Panel adopted a numbered classification.

The most common type, neurofibromatosis 1 or NF-1 (previously known as von Recklinghausen's neurofibromatosis or peripheral neurofibromatosis) is an autosomal dominant disorder affecting about 1 in 4,000 individuals. Multiple hyperpigmented areas (café-au-lait macules) and neurofibromas are characteristic.

Neurofibromatosis 2 or NF-2 (previously known as bilateral acoustic neurofibromatosis or central neurofibromatosis) is an autosomal dominant disorder occurring in about 1 in 50,000 individuals. Eighth nerve tumors are characteristic, but other intracranial and intraspinal tumors are common.

There is a considerable variation of manifestations even within a family, confounding classification in some patients. This variability affects management because it is often not possible to predict the course in an individual patient. Other forms of neurofibromatosis may exist, but their precise classification is not possible at the present time.

The NF-1 gene has just been localized to chromosome 17, and the NF-2 locus is probably on chromosome 22. Continued rapid scientific progress is expected in the molecular genetics of both NF-1 and NF-2. This will directly influence classification, patient care, counseling of families, and research.

There are no cures for the neurofibromatoses, and treatment consists of amelioration of the clinical symptoms. Many short- and long-term management issues were addressed by the Consensus Conference, leading to recommendations for care at diagnosis and during routine followup and for research.

This NIH Consensus Development Conference on Neurofibromatosis was convened by the National Institute of Neurological and Communicative Disorders and Stroke, the National Cancer Institute, and the National Institutes of Health Office of Medical Applications of Research, on July 13-15, 1987, to address issues concerning the diagnosis and management of the neurofibromatoses. The conference brought together a wide range of scientists and medical experts, including specialists in neurology, pediatric neurology, neurosurgery, pediatrics, genetics, and other relevant fields. Presentations were made by experts, and discussions with the audience and the Consensus Panel followed each presentation. Questions addressed by the panel were as follows:

- What are the various clinical types of neurofibromatosis, and what are their frequencies and diagnostic criteria?
- What are the recommendations for care of patients and their families at diagnosis and during routine followup?
- What are the management options for major manifestations of neurofibromatosis?
- What are the key research areas that will improve our knowledge about prevention, diagnosis, and treatment of neurofibromatosis?

The first three questions were addressed separately for NF-1, NF-2, and variant forms.

## Neurofibromatosis 1

### What Are the Diagnostic Criteria

The diagnostic criteria for NF-1 are met in an individual if two or more of the following are found:

- Six or more café-au-lait macules over 5 mm in greatest diameter in prepubertal individuals and over 15 mm in greatest diameter in postpubertal individuals.
- Two or more neurofibromas of any type or one plexiform neurofibroma.
- Freckling in the axillary or inguinal region.
- Optic glioma.
- Two or more Lisch nodules (iris hamartomas).
- A distinctive osseous lesion such as sphenoid dysplasia or thinning of long bone cortex with or without pseudarthrosis.
- A first-degree relative (parent, sibling, or offspring) with NF-1 by the above criteria.

Other disorders of pigmentation such as McCune-Albright or Watson syndrome can be confused with NF-1.

### What Are the Recommendations for Care of Patients and Their Families at Diagnosis and During Routine Followup?

Once a diagnosis of NF-1 is made, the initial evaluation of patients without major complications can be made in a standard clinical setting.

- History should focus on symptoms possibly associated with the disorder such as cognitive or psychomotor deficits, pain, vision problems, progressive neurologic deficit, and constipation.
- Family history should include grandparents, great aunts and uncles, and their descendants. When possible, an effort should be made to locate medical records of affected first- and second-degree relatives.
- Physical examination should give particular attention to possible manifestations of the disorder such as hypertension, scoliosis and other skeletal anomalies, macrocephaly, focal neurological deficits (impaired vision, ptosis, optic atrophy), developmental disabilities, proptosis, Lisch nodules, short stature, signs of precocious puberty or hypogonadism, cafe'-au-lait macules, and neurofibromas.
- Tests should be dictated by findings on clinical evaluation. Laboratory tests in asymptomatic patients are unlikely to be of value, particularly computerized tomography (CT), magnetic resonance imaging (MRI), electroencephalography (EEG), and evoked potentials.
- Counseling must be provided for all patients and their families and should include:
  - Prognosis. The natural history of the disorder is poorly understood but includes serious complications in some individuals. The probability of these serious complications has been overstated; an individual's risk is limited. Counseling should note the risks of progression during puberty or pregnancy.
  - Genetics. Each child born to an affected person has a 50-percent chance of having NF-1, but manifestations of the disorder vary among individuals within affected families. Genetic techniques will soon permit prenatal diagnosis.
  - Psychological and social adjustment. Issues to be addressed include anxieties regarding the uncertainties of the disorder's course and fear of possible disfigurement and of developing other severe complications.
  - Family members. Family members, particularly first-degree relatives, should be evaluated to determine whether they have NF-1. Appropriate counseling should accompany such assessments.
  - Followup. Annual visits (more often if indicated) should be scheduled with a clinician familiar with the disorder.
  - Resources for NF-1 patients. Patients should be offered the addresses and telephone numbers of specialized clinics that provide a broad array of relevant clinical expertise and of appropriate lay organizations that can give additional information and facilitate access to patient support groups.
- A written report should summarize the clinical findings, test results, and information conveyed through the counseling.

Annual followup examination and counseling should parallel the initial assessment just described, with emphasis on new symptoms and progressive deficits.

Parents caring for a child with NF-1, and other family members, have a great need for accurate information, psychological support, and interaction with other affected families. Clinicians caring for patients with NF-1 should view involvement of family members as a major aspect of care.

### What Are the Management Options for the Major Manifestations of Neurofibromatosis 1?

When symptoms suggest major manifestations of NF-1, the patient should be referred to the appropriate specialist and evaluated by x-ray, MRI, or laboratory tests. Surgical intervention and radiation therapy should be used sparingly and only when it is clear that they will contribute to the patient's well-being. The most common complications deserve special mention.

#### Optic Glioma

Optic glioma occurs in some patients with NF-1 and may cause progressive visual loss. However, most optic gliomas are nonprogressive and should be followed with annual ophthalmologic examinations. MR and CT imaging are the best methods to document their size, shape, and extension.

Because the visual impairment associated with optic glioma is probably not altered by intervention, surgical resection, radiation, or chemotherapy should only be used in special circumstances such as disfiguring orbital masses or large tumors that are compressing adjacent structures.

#### Other Neural Tumors

These tumors should be managed in NF-1 patients in the same manner as they are in the general population. When a focal, resectable lesion is identified that is causing progressive neurological deficit by compressing the brain or spinal cord, it should be surgically removed.

Tumors within the central nervous system are frequently not resectable, and therefore surgical therapy is not warranted unless they are causing increased intracranial pressure or distorting neighboring structures. When malignant change is suspected, biopsy, internal decompression, chemotherapy, or radiation therapy may be indicated.

#### Orthopedic Problems

The two most common orthopedic problems associated with NF-1 are kyphoscoliosis and tibial bowing. Both may benefit from early intervention and should be managed by an orthopedist familiar with the complications of NF-1. Patients with kyphoscoliosis should have MRI of the spine to investigate the possibility of focal spinal cord lesions. They should be fitted early with bracing, followed closely with spine x-rays, and if deformity progresses, undergo spinal fusion. Tibial bowing should be treated by bracing in an attempt to prevent fracture and subsequent pseudarthrosis.

#### Disfigurements

Disfigurements that may benefit from intervention are common, although the need for major surgery is less frequent. Removal of neurofibromas may contribute to maintenance of function and psychological well-being. Sphenoid dysplasia occurs in a small number of patients. The resulting facial asymmetry and exophthalmos may be improved by reconstructive surgery. Deformities secondary to large soft tissue masses are difficult to repair and have a tendency to recur.

#### Developmental Disabilities

Language disorders and learning disabilities mandate neuropsychologic assessment so as to provide therapists and educators with information upon which to base remediation.

#### Vascular Problems

Hypertension in patients with NF-1 must be fully evaluated with particular emphasis on identifying treatable causes such as pheochromocytoma and renal vascular stenosis. Other vascular disorders must be handled on an individual basis in the same manner as they would be in the general population.

#### Malignancy

Although malignancies are rare in NF-1, there is an increased incidence of sarcomas and leukemias, especially in childhood. When malignancies are detected, NF-1 patients should be evaluated and treated the same as other patients. Because NF-1 patients also have an increased incidence of second malignancies, they must have close, long-term followup.

## Neurofibromatosis 2

### What Are the Diagnostic Criteria

The criteria for NF-2 are met by an individual who has:

1. Bilateral eighth nerve masses seen with appropriate imaging techniques (e.g., CT or MRI), or
2. A first-degree relative with NF-2 and either:
  1. unilateral eighth nerve mass, or
  2. two of the following:
    - neurofibroma.
    - meningioma
    - glioma.
    - schwannoma.
    - juvenile posterior subcapsular lenticular opacity.

### What Are the Recommendations for Care of Patients and Their Families at Diagnosis and During Routine Followup?

Once a diagnosis of NF-2 is made, the initial evaluation of patients without major complications can be made in a standard clinical setting.

- History should focus on symptoms possibly associated with the disorder such as hearing loss, tinnitus, dizziness, loss of balance, pain, headache, and seizures.
- Family history should include grandparents, great aunts and uncles, and their descendants. When possible, an effort should be made to locate medical records of affected first- and second-degree relatives.
- Physical examination should give particular attention to possible manifestations of the disorder such as cafe'-au-lait macules and neurofibromas. Neurological assessment should emphasize cranial nerves, balance, and coordination.
- Tests must include an audiogram and brain stem auditory evoked responses (BAER). MRI is the neuroimaging procedure of choice to be used in patients with evidence of hearing impairments or abnormal BAER. Tests of vestibular function may be useful adjuncts to BAER screening because eighth nerve tumors develop on the vestibular division. If no MRI has been performed by puberty, it should be obtained. Other tests should be performed as dictated by findings on clinical evaluation.
- Counseling must be provided for all patients and their families and should include:
  - Prognosis. The natural history of the disorder is unpredictable. The major risks for the patient are loss of hearing and vestibular function. Underwater activities and climbing pose particular risks. There is an increased risk of developing intracranial and intraspinal neoplasms.
  - Genetics. Each child born to an affected person has a 50 percent chance of having NF-2, but the manifestations of the disorder vary among individuals within affected families. Genetic techniques will soon permit prenatal diagnosis. Counseling should also note that pregnancy may accelerate the growth of eighth nerve tumors.
  - Psychological and social adjustment. Issues to be addressed include anxieties regarding the uncertainties of the disorder's course and fear of hearing loss and other complications. Counseling should also include a realistic discussion of the implication of possible hearing loss for schooling, career planning, and use of alternative communication methods.
  - Family members. Family members, particularly first-degree relatives, should be evaluated periodically to determine whether they have NF-2. Appropriate counseling should accompany such assessments.
  - Followup. Annual visits (more often if indicated) should be scheduled with a clinician familiar with the disorder.
  - Resources for NF-2 patients. Patients should be offered the addresses and telephone numbers of specialized clinics that provide a broad array of relevant clinical expertise and of appropriate lay organizations that can give additional information and facilitate access to patient support groups.
- A written report should summarize the clinical findings, test results, and the information conveyed through counseling.

Annual followup examination and counseling should parallel the initial assessment just described.

Parents caring for a child with NF-2, and other family members, have a great need for accurate information, psychological support, and interaction with other affected families. Clinicians caring for patients with NF-2 should view involvement of family members as a major aspect of care.

### What Are the Management Options for the Major Manifestations of Neurofibromatosis 3?

When eighth nerve tumors are found, patients need to be advised about the possibility of total hearing loss at some time in the future. A management strategy should be discussed and the patient referred to a center with experience in determining the best treatment plan for long-term preservation of hearing. Because the possibility of removing a tumor with minimal injury to the auditory nerve is much better when the tumor is small, consideration should be given to attempting to remove one progressive tumor while bilateral hearing remains. If the tumor is successfully removed with preservation of hearing on that side, consideration should be given to removing the second tumor. If hearing is not preserved by removing the first tumor, it may be better to follow the second tumor as long as possible and then perform a subtotal removal in an attempt to prevent deafness. An MRI scan of the cervical spine should be performed before surgery to detect intraspinal tumors that might damage the spinal cord during surgery. All surgery for eighth nerve tumors should use auditory and facial nerve monitoring in an attempt to minimize the possibility of nerve injury. Stereotactic radiation therapy may be a treatment option for these tumors.

Other intracranial or intraspinal tumors occur in many patients but should be surgically treated only when they can be implicated as the cause of progressive disease.

#### Other Forms

Some patients, particularly children, have insufficient findings to meet NF-1 and NF-2 criteria. These patients require annual followup evaluations. Molecular genetics may permit a diagnosis of NF-1 or NF-2 in these patients. This may require modification of current NF-1 or NF-2 diagnostic criteria. Patients who do not fit into the NF-1 or NF-2 group by clinical or genetic criteria may, in the future, constitute the basis for establishing additional types of NF. These patients may require referral for more precise diagnosis or treatment of specific complications.

### What Are the Key Research Areas That Will Improve Our Knowledge About Prevention, Diagnosis, and Treatment of Neurofibromatosis?

#### Molecular Genetics and Cell Biology

Molecular genetics provides unique opportunities for research in the neurofibromatoses. The gene for NF-1 has just been mapped to a site on chromosome 17 using a number of large kindreds. Recent evidence has localized NF-2 to chromosome 22 through analysis of tumor DNA. The immediate issues that must be addressed for NF-1 and NF-2 are the possibility of genetic heterogeneity among families and the identification of useful DNA markers closely flanking the genes.

In the near future, it will be possible to accurately trace the NF-1 and NF-2 genes in families by genetic linkage. A consequence of the identification of closely linked markers will be the availability of prenatal diagnosis. Individuals with minimal expression can be definitively diagnosed. Those individuals demonstrated not to carry the NF genes can be removed from the at-risk category.

The isolation of the NF-1 and NF-2 genes can be accomplished by recombinant DNA technology. Because many questions about the pathophysiology of the neurofibromatoses can be addressed through knowledge of the structure of the relevant genes, strong support of this line of investigation is recommended. Culture studies using Schwann and other related cell types clearly will be important. Signals leading to modulation of NF gene expression and to the variable phenotypes seen in vivo may be revealed in this in vitro approach.

The analysis of tumor DNA from NF-2 patients has already demonstrated the value of direct studies of tumor material. The elucidation of the mechanistic basis of tumor formation in the neurofibromatoses is likely to have significant implications for other neoplastic disorders. Therefore, it is recommended that tumor tissue from NF patients continue to be made accessible to investigators who are attempting to identify the basis of abnormal growth control.

Appropriate animal models for NF-1 and NF-2 will be desirable for testing potential therapies under in vivo conditions and for extending cell culture findings. Molecular genetic techniques provide an avenue to the development of such animal models. The development of such models is strongly recommended.

#### Natural History and Treatment

It is important to determine the natural history of NF, including predictors of disease progression, site-specific risks for subsequent neoplasia, and survival patterns. A source of patients and family members for genetic studies is essential. Research protocols for evaluation of specific interventions are needed. Centralized reporting systems that are well conceived and organized will be required to address these issues.

## Conclusion

The clinical and genetic analyses of NF have now converged to provide a new framework for the understanding of NF. The assignment of individual patients to NF-1 and NF-2, based on distinctive clinical features, is now confirmed by localization of the genes to separate chromosomes. Clinical management differs for NF-1 and NF-2. We now recognize that NF-1 individuals often do not experience major complications requiring intervention. However, when present, these complications represent a major burden. Generally, complications can be recognized by history and examination, minimizing the need for routine laboratory testing. The major feature of NF-2, bilateral eighth nerve tumor leading to deafness, is frequent. Significant progress has been made in the surgical treatment of these lesions.

Research on the neurofibromatoses is at an exciting juncture. Isolation of the NF-1 and NF-2 genes can now proceed by well-established methods. Research opportunities include defining the natural history of the disorder, its complications, and the effects of their treatment; elucidating molecular genetic mechanisms; and clarifying the biological processes underlying the neoplastic lesions.

## Consensus Development Panel

- >David A. Stumpf, M.D., Ph.D.
- Panel Chairperson
- Professor of Pediatrics and Neurology
- Vice Chairman
- Department of Neurology
- Northwestern University Medical School
- Chief
- Pediatric Neurology
- Children's Memorial Hospital
- Chicago, Illinois

- >John F. Alksne, M.D.
- Professor and Chairman
- Neurological Surgery
- University of California, San Diego
- San Diego, California

- >John F. Annegers, Ph.D.
- Professor of Epidemiology
- University of Texas
- School of Public Health
- Houston, Texas

- >Sarah S. Brown, M.P.H.
- Study Director
- Institute of Medicine
- National Academy of Sciences
- Washington, D.C.

- >P. Michael Conneally, Ph.D.
- Professor of Medical Genetics and Neurology
- Indiana University Medical Center
- Indianapolis, Indiana

- >David Housman, Ph.D.
- Professor
- Department of Biology
- Center for Cancer Research
- Massachusetts Institute of Technology
- Cambridge, Massachusetts

- >Mark F. Leppert, Ph.D.
- Senior Research Associate
- Howard Hughes Medical Institute
- University of Utah Medical Center
- Salt Lake City, Utah

- >J. Philip Miller, Ph.D.
- Associate Professor
- Division of Biostatistics
- Washington University Medical School
- St. Louis, Missouri

- >Melvin L. Moss, Ph.D.
- Consultant and Former Director of Research
- Muscular Dystrophy Association
- National Advisory Board
- Williams Syndrome Association
- Verona, Pennsylvania

- >Anthony J. Pileggi, M.D.
- Neurodevelopmental Pediatrics
- Geisinger Medical Center
- Danville, Pennsylvania

- >Isabelle Rapin, M.D.
- Professor of Neurology and Pediatrics (Neurology)
- Albert Einstein College of Medicine
- Bronx, New York

- >Richard C. Strohman, Ph.D.
- Professor of Human Biology
- Department of Zoology
- University of California, Berkeley
- Berkeley, California

- >Larry W. Swanson, Ph.D.
- Senior Member
- The Salk Institute for Biological Studies
- Investigator
- Howard Hughes Medical Institute
- Adjunct Professor
- University of California, San Diego
- La Jolla, California

- >Andrew Zimmerman, M.D.
- Pediatric Neurologist
- Knoxville Neurology Clinic
- The University of Tennessee Medical
- Center at Knoxville
- Knoxville, Tennessee

## Speakers

- >Jonathan Buckley, Ph.D., M.B.B.S.
- "Opportunities for Research on Etiology Within Cooperative Clinical Trials Groups"
- Assistant Professor
- Department of Preventive Medicine
- Children's Cancer Research Group
- Pasadena, California

- >John C. Carey, M.D., M.P.H.
- "von Recklinghausen Neurofibromatosis: General, Historical, and Overview"
- Chief
- Division of Medical Genetics
- Associate Professor of Pediatrics
- University of Utah School of Medicine
- Cancer Research Wing
- Salt Lake City, Utah

- >Alvin H. Crawford, M.D.
- "Management of Skeletal Complications in von Recklinghausen's Neurofibromatosis"
- Director
- Pediatric/Orthopedic Surgery
- Children's Hospital Medical Center
- Cincinnati, Ohio

- >Martha Bridge Denckla, M.D.
- "von Recklinghausen's Neurofibromatosis: Neurological and Cognitive Assessment of Cognitive Functions in Neurofibromatosis"
- Developmental Neurology Branch
- Convulsive, Developmental, and Neuromuscular Disorders Program
- National Institute of Neurological and Communicative Disorders and Stroke
- National Institutes of Health
- Bethesda, Maryland

- >Roswell Eldridge, M.D.
- "Bilateral Acoustic Neurofibromatosis: Genetic Basis, Natural History, and Counseling"
- Clinical Genetic Studies
- Neuroepidemiology Branch
- National Institute of Neurological and Communicative Disorders and Stroke
- National Institutes of Health
- Bethesda, Maryland

- >Thomas B. Fitzpatrick, M.D., Ph.D.
- "The Melanocyte in von Recklinghausen's Neurofibromatosis"
- Professor of Dermatology
- Harvard Medical School
- Massachusetts General Hospital
- Boston, Massachusetts

- >James F. Gusella, Ph.D.
- "Genetics, von Recklinghausen's, and Bilateral Acoustic Neuroma"
- Director for Neurogenetics Laboratory
- Massachusetts General Hospital
- Harvard Medical School
- Neurogenetics Laboratory
- Boston, Massachusetts

- >Judith Goslin Hall, M.D., F.A.A.P., F.R.C.P.(C),F.C.C.M.G., F.A.B.M.G.
- "Penetrance, Variability, and Maternal Factors"
- Professor, Medical Genetics
- University of British Columbia
- Grace Hospital
- Vancouver, British Columbia
- CANADA

- >William F. Hoyt, M.D.
- "Optic Glioma"
- Professor of Ophthalmology, Neurosurgery, and
- Neurology
- University of California, San Francisco
- San Francisco, California

- >Susan M. Huson, M.B., Ch.B., M.R.C.P.
- "Research Directions 1"
- "Genetic Linkage Studies of von Recklinghausen Neurofibromatosis"
- Senior Registrar in Clinical Genetics
- Division of Inherited Metabolic Disease
- Clinical Research Centre
- Harrow, Middlesex
- ENGLAND

- >Bruce R. Korf, M.D., Ph.D.
- "Overall Summary: Management of VRNF"
- Assistant Professor of Neurology
- Director of Clinical Genetics
- Harvard Medical School
- Children's Hospital
- Boston, Massachusetts

- >Edward Raymond Laws, Jr., M.D.
- "The Neurosurgical Mangement of Optic Nerve Glioma"
- Professor of Neurologic Surgery
- Joseph I. and Barbara Ashkins Professor of Surgery
- Mayo Clinic
- Mayo Medical School
- Rochester, Minnesota

- >G. Dean MacEwen, M.D.
- "Management of Skeletal Complications in von Recklinghausen's Neurifibromatosis"
- Chairman
- Department of Pediatric Orthopedic Surgery
- Professor of Orthopedics
- Louisiana State University at New Orleans
- New Orleans, Louisiana

- >Robert L. Martuza, M.D.
- "Bilateral Acoustic Neurofibromatosis: Diagnosis and Natural History"
- Associate Professor of Surgery
- Harvard Medical School
- Associate Visiting Neurosurgeon
- Director
- Neurofibromatosis Clinic
- Massachusetts General Hospital
- Boston, Massachusetts

- >Anna T. Meadows, M.D.
- "Management of Malignancy in von Recklinghausen's Neurofibromatosis"
- Professor of Pediatrics
- University of Pennsylvania School of Medicine
- Children's Hospital of Philadelphia
- Philadelphia, Pennsylvania

- >John J. Mulvihill, M.D.
- "Overview and Natural History of Neurofibromatosis"
- Chief
- Clinical Genetics Section
- Clinical Epidemiology Branch
- National Cancer Institute
- Director
- Interinstitute Medical Genetics Program
- National Institutes of Health
- Bethesda, Maryland

- >Georg Norén, M.D.
- "Stereotactic Radiation Treatment in Bilateral Acoustic Neuroma"
- Associate Professor
- Department of Neurosurgery
- Karolinska Hospital
- Stockholm
- SWEDEN

- >Robert G. Ojemann, M.D.
- "Management of Patients with Bilateral Acoustic Neuroma"
- Professor of Surgery
- Harvard Medical School
- Senior Neurosurgeon
- Massachusetts General Hospital
- Boston, Massachusetts

- >John A. Persing, M.D.
- "Reconstructive Surgery of Patients With Neurofibromatosis"
- Associate Professor of Plastic and Neurological
- Surgery
- Department of Plastic Surgery
- University of Virginia Medical Center
- Charlottesville, Virginia

- >David E. Pleasure, M.D.
- "Biology of Neurofibroma Schwann-Like Cells"
- Vice Chairman of Neurology
- Professor of Neurology and Pediatrics
- University of Pennsylvania
- Director of Research of Pediatric Neurology
- Joseph Stokes, Jr., Research Institute
- Children's Hospital
- Philadelphia, Pennsylvania

- >Albert L. Rhoton, Jr., M.D.
- "General Management of Acoustic Neuromas"
- Chairman
- Department of Neurosurgery
- R.D. Keene Family Professor
- University of Florida College of Medicine
- J. Hillis Miller Health Center
- Gainesville, Florida

- >Vincent M. Riccardi, M.D.
- "Alternative Forms of Nueofibromatosis"
- Professor of Medicine
- Baylor College of Medicine
- Houston, Texas

- >Kenneth N. Rosenbaum, M.D.
- "Management at Diagnosis and on Followup"
- Director
- Clinical Genetics
- Children's Hospital National Medical Center
- Washington, D.C.

- >Alonzo H. Ross, Ph.D.
- "Biology of Neurofibromatosis Schwann-Like Cells"
- Assistant Professor Wistar Institute
- Assistant Professor of Neurology
- Department of Neurology
- University of Pennsylvania Medical School
- Philadelphia, Pennsylvania

- >Allan E. Rubenstein, M.D.
- "Neurofibromatosis: Other Forms"
- Associate Professor of Neurology
- Department of Neurology
- Mount Sinai School of Medicine
- New York, New York

- >Kenneth H. Sonnenfeld, Ph.D.
- "Growth Factor-Receptors in Neurofibromatosis"
- Fish & Neave
- New York, New York

- >Sven Asger Sørensen, M.D.
- "Morbidity and Mortality in Neurofibromatosis"
- Associate Professor
- Institute of Medical Genetics
- University of Copenhagen
- The Panum Institute
- Copenhagen N
- DENMARK

- >Mary H. Waziri, M.D.
- "Psychosocial Aspects of von Recklinghausen Neurofibromatosis"
- Associate
- Department of Pediatrics
- Division of Medical Genetics
- University of Iowa Hospitals
- Iowa City, Iowa

## Planning Committee

- >Joseph S. Drage, M.D.
- Planning Committee Chairperson
- Chief
- Developmental Neurology Branch
- Division of Convulsive, Developmental, and Neuromuscular Disorders
- National Institute of Neurological and Communicative Disorders and Stroke
- National Institutes of Health
- Bethesda, Maryland

- >Michael J. Bernstein
- Director of Communications
- Office of Medical Applications of Research
- National Institutes of Health
- Bethesda, Maryland

- >Patricia Duncan
- Technical Publications Writer
- Office of Scientific and Health Reports
- National Institute of Neurological and Communicative Disorders and Stroke
- National Institutes of Health
- Bethesda, Maryland

- >Jerry M. Elliott
- Program Analyst
- Office of Medical Applications of Research
- National Institutes of Health
- Bethesda, Maryland

- >Harry Handelsman, D.O.
- Health Science Analyst
- Office of Health Technology Assessment
- Rockville, Maryland

- >Robert L. Martuza, M.D.
- Associate Professor of Surgery
- Harvard Medical School
- Associate Visiting Neurosurgeon
- Director
- Neurofibromatosis Clinic
- Massachusetts General Hospital
- Boston, Massachusetts

- >Manfred D. Muenter, Ph.D.
- Associate Professor of Neurology
- Department of Neurology
- Mayo Medical School
- Rochester, Minnesota

- >John J. Mulvihill, M.D.
- Chief
- Clinical Genetics Section
- Clinical Epidemiology Branch
- National Cancer Institute
- Director
- Interinstitute Medical Genetics Program
- National Institutes of Health
- Bethesda, Maryland

- >Ntinos C. Myrianthopoulos, Ph.D.
- Research Geneticist
- Developmental Neurology Branch
- National Institute of Neurological and Communicative Disorders and Stroke
- National Institutes of Health
- Bethesda, Maryland

- >Martin Rose, M.D., J.D.
- Former Chief Medical Officer
- Office of Medical Applications of Research
- National Institutes of Health
- Bethesda, Maryland

- >Zekin A. Shakhashiri, M.D., M.Sc., M.P.H.
- Senior Medical Advisor
- National Institute of Neurological and Communicative Disorders and Stroke
- National Institutes of Health
- Bethesda, Maryland

- >David A. Stumpf, M.D., Ph.D.
- Professor of Pediatrics and Neurology
- Vice Chairman
- Department of Neurology
- Northwestern University Medical School
- Chief
- Pediatric Neurology
- Children's Memorial Hospital
- Chicago, Illinois

## Conference Sponsors

- >National Institute of Neurological and Communicative Disorders and Stroke
- Murray Goldstein, D.O.
- Director

- >National Cancer Institute
- Vincent T. DeVita, Jr., M.D.
- Director

- >Office of Medical Applications Of Research
- Itzhak Jacoby, Ph.D.
- Acting Director