# Antenatal Diagnosis

National Institutes of Health Consensus Development Conference Statement, March 5-7, 1979

## Introduction

A Consensus Development Conference on Antenatal Diagnosis was held at the National Institutes of Health on March 5-7, 1979. The purpose of the conference was to assess the state of the art of techniques used in prenatal diagnosis; the legal, ethical, and social and economic implications of their use; appropriate applications of these techniques at present; and needs for additional research on their use.

The NIH consensus development program brings together practicing physicians, biomedical research scientists, consumers, and others in an effort to reach general agreement on the safety and efficacy of a medical technology, whether it be a drug, device or procedure.

At the antenatal diagnosis meeting, three broad categories of obstetrical techniques were discussed:

- Predictors of hereditary disease and congenital defects. These include mid-trimester amniocentesis, fetoscopy, alpha-fetoprotein measurements, and ultrasound;
- Predictors of fetal maturity, including third-trimester amniocentesis and ultrasound; and
- Predictors of fetal distress, including monitoring during labor.

Before the meeting, task forces prepared preliminary reports on each of the three topics, summarizing the issues and giving recommendations. These draft reports were disseminated widely to obstetrical researchers, practicing obstetricians and gynecologists, lawyers, bioethicists, consumers, and voluntary associations concerned with pregnancy and childbirth. The reports prompted many people to submit written statements before the conference and provoked much debate during the meeting. As a result of this discussion, task force members reviewed and in some cases revised the recommendations made in draft reports. Final reports were published in August of 1979.

## Predictors of Hereditary Disease or Congenital Defects

The 12-member Task Force on Predictors of Hereditary Disease or Congenital Defects, chaired by Dr. Michael M. Kaback (Professor of Pediatrics and Medical Genetics, U.C.L.A. School of Medicine) weighed the risks and benefits of amniocentesis and other procedures that enable physicians to recognize defective fetuses as early as the fourth month of pregnancy.

They recommended that health professionals responsible for the care of pregnant women should be aware of techniques now available for early diagnosis of fetal defects, and should be prepared to identify and advise couples who are likely candidates for prenatal diagnostic services.

Amniocentesis--a procedure in which amniotic fluid and fetal cells are drawn out of the uterus for study--is now a widely accepted clinical practice, the panel found. They recommended that any pregnant woman age 35 or older should be advised about the possibility of undergoing amniocentesis (for detection of chromosomal abnormalities in the fetus). Other situations in which a pregnant woman should be offered the option of amniocentesis are:

- if she has had a chromosomally abnormal child in the past;
- if three or more of her past pregnancies have ended in miscarriages, or if her husband's previous wife experienced several miscarriages;
- if she or her mate is known to have a chromosomal abnormality;
- if there is a history of Down syndrome or some other chromosomal abnormality in her family or her spouse's family;
- if she has male relatives with Duchenne muscular dystrophy or severe hemophilia, or if she is suspected of carrying some other harmful gene on one of her X chromosomes;
- if her fetus is at a higher-than-usual risk for some hereditary error of metabolism detectable in utero; or
- if her fetus is at increased risk for a neural tube defect.

Although a physician may inform a woman that she is at higher-than-usual risk of bearing a defective child and may acquaint her with the existence and uses of amniocentesis, the final decision to undergo the procedure must be her own, the panel stated. Health care professionals should provide patients with the information they need to make such decisions.

Echosonography (ultrasound) is a valuable technique for viewing the fetus and placenta prior to amniocentesis, according to the panel, which strongly recommended its use in this context. However, more clinical research will be required before ultrasound can be relied upon as a tool for diagnosis of physical defects in its own right.

Fetoscopy and fetal blood sampling remain experimental and are not ready for general use at this time, according to the panel. These techniques carry a higher risk to the fetus than do amniocentesis or echosonography, and should not be used in situations where safer methods would suffice.

Measurement of alpha-fetoprotein (AFP) in amniotic fluid is now an accepted practice for detecting neural tube defects in pregnancies at special risk for these disorders, the panel found. It may soon be possible to screen large numbers of pregnancies for neural tube defects by measuring AFP in the blood serum of obstetrical patients; however, this screening procedure cannot be recommended for wide use until pilot studies prove its efficacy.

## Predictors of Fetal Maturation

Ultrasonography and third-trimester amniocentesis are valuable, effective tools for determining fetal maturity in high-risk pregnancies and in other pregnancies where the baby may have to be delivered before term. In fact, appropriate use of these techniques can virtually eliminate the problems of prematurity and respiratory distress syndrome (RDS) following scheduled cesarean section, problems which have complicated 15 percent of such deliveries. However, these procedures should be used only when indicated, and should be studied further for possible long-range effects on both mother and fetus.

These were among the recommendations made by the Task Force on Predictors of Fetal Maturation, which discussed obstetrical techniques used to determine the age of a fetus and whether its lungs are mature enough to permit survival outside the uterus. Two such techniques are available: ultrasonography, and amniocentesis in the last three months of pregnancy. The amniotic fluid can be analyzed for certain components that indicate lung maturity by using either the L/S ratio test or the "shake test."

Panel members agreed that the potential benefits of both techniques in preventing premature deliveries far outweigh the costs and possible risks. However, because the long-range effects are unknown, the panel recommended against routine use of ultrasound for all pregnant women and cautioned that both ultrasound and third-trimester amniocentesis should be used only when indicated: in high-risk pregnancies, in cases where the woman has had previous cesarean sections, and in other cases where the physician thinks information on fetal maturity may be needed. Their specific recommendations were:

- If the patient's obstetrical history suggests that a cesarean section may be necessary, a sonogram should be taken before the 26th week to measure the fetal biparietal diameter (head width), an indicator of fetal maturity. If there is still some question about the age of the fetus, a second sonogram should be taken early in the third trimester; together, the two measurements provide the baby's growth rate, and can be used to accurately estimate its age.
- If the high-risk pregnant woman is not seen until later in pregnancy, ultrasound is not as accurate for judging fetal age and amniocentesis should be used to obtain reliable information on fetal lung maturity. (The panel recommended sonography to determine the position of fetus and placenta before amniocentesis.) Of the two tests that can be done on amniotic fluid--the L/S ratio test and the "shake test"--the panel said the L/S ratio is a more reliable indicator of fetal maturity. In both the L/S ratio and shake tests, there is an intermediate range of values which are hard to interpret and therefore unreliable predictors of whether a baby will develop RDS. However, with an L/S ratio of 2 or greater, there is a better than 99 percent chance that the baby will not have RDS.

Panel members pointed out that both methods require considerable expertise for accurate results--the shake test in particular is prone to inaccuracy when performed without caution. To minimize problems, the task force recommended post-graduate training in amniocentesis and ultrasonography for physicians with no experience in doing the procedures, and special care in performing the laboratory tests.

Suggesting directions for future research, task force members said there is a need for more accurate indicators of lung immaturity because of uncertain middle-range values in the L/S ratio test. They cited the "lung profile" and other measures as promising developments. Also, standards are needed for the manufacture of ultrasound machines and for both technical and professional proficiency in doing ultrasonography and amniocentesis.

The task force was chaired by Dr. Joseph Dancis, Chairman of the Department of Pediatrics, New York University School of Medicine.

## Predictors of Fetal Distress

Agreement was reached by the Task Force on Predictors of Fetal Distress that, at present, the use of electronic fetal monitoring (EFM) should be strongly considered in high risk patients. Among the specific circumstances which the task force felt could benefit from the use of electronic fetal monitoring are expected low birth weight, premature, postmature or intrauterine growth retarded babies; women with medical complications of pregnancy; the presence of meconium in the amniotic fluid; and situations where abnormal fetal heart rate is detected with a stethoscope (auscultation).

In the absence of identifiable risk factors, the task force found periodic auscultation^*^ of the fetal heart rate to be an acceptable way to assess fetal condition for women at low risk for complications during labor and delivery. The panel pointed out that present data are inadequate to permit final conclusions, but found no evidence at present that electronic fetal monitoring reduces mortality or morbidity in low risk patients. Nonetheless, it recognized that under certain circumstances, mothers or physicians may choose to use EFM even in low risk situations.

* The panel defined periodic auscultation to include auscultation of the fetal heart every 15 minutes during the first stage of labor and every five minutes during the second stage. In either case, the fetal heart should be auscultated within 30 seconds of the end of a contraction.

In any case--whether or not EFM is employed--the task force emphasized that EFM should not be a substitute for clinical judgment. Any form of monitoring, the panel said, is only one measure of fetal status.

Since unexpected complications may arise during labor, the panel said that all hospitals and birthing centers providing maternity care should have the necessary trained staff and equipment to assess carefully the status of each fetus during labor and to take appropriate action.

The panel also strongly urged that fetal scalp blood pH determination be used as an adjunct to electronic fetal heart rate monitoring. Scalp blood testing provides additional information that may reduce monitoring-associated cesarean rates.

The task force cautioned that when electronic fetal monitoring is used, personnel should be well versed in the potential hazards. To minimize risk, the task force recommended that:

1. Placement of the fetal scalp electrode and intrauterine pressure catheter should be performed very carefully and with the thorough understanding of the proper techniques to minimize risk of infection and injury to both mother and child.
2. Prolonged supine position of the mother should be avoided.
3. Maternal mobility should not be unnecessarily limited.
4. Artificial rupture of the amniotic sac solely for internal electronic fetal monitoring should not be routine.

The task force recognized that electronic fetal monitoring may be considered intrusive by women who want a natural, family centered birth. For this reason, the group said that the proper use of EFM should include a discussion with the patient of her wishes, concerns, and questions about all forms of fetal monitoring. The panel recommended that women have the opportunity to discuss the subject during the course of prenatal care and again upon admission to the labor suite.

The task force also identified some specific areas where additional research is needed. These include:

1. Research into the effects of hypoxia (decreased oxygen supply) on the fetus and newborn.
2. Research to identify risk factors for fetal distress during birth, especially fetal distress which is amenable to EFM.
3. Additional clinical trials of EFM in various categories of high risk patients to gather data on criteria for use, efficacy, and risk.
4. Development of non-invasive methods of fetal monitoring.

The Task Force on Predictors of Fetal Distress was chaired by Dr. Frederick P. Zuspan, Professor and Chairman of the Department of Obstetrics and Gynecology at the Ohio State University College of Medicine.

## Task Force on Predictors of Hereditary Disease or Congenital Defects

Michael M. Kaback, M.D. (Chairman)
- Professor of Pediatrics and Medicine
- UCLA School of Medicine
- Harbor-UCLA Medical Center
- Torrance, California

Duane Alexander, M.D
- Project Officer, NICHD
- Bethesda, Maryland

Robert L. Brent, M.D
- Professor and Chairman
- Department of Pediatrics
- Jefferson Medical College
- Philadelphia, Pennsylvania

Barbara F. Crandall, M.D
- Associate Professor of Pediatrics and Psychiatry
- UCLA Center for the Health Sciences
- Los Angeles, California

Ezra Davidson, M.D
- Professor and Chairman
- Department of Obstetrics and Gynecology
- Charles R. Drew Postgraduate Medical School
- Martin Luther King, Jr. General Hospital
- Los Angeles, California

Carla Dowben, J.D
- Associate Professor of Obstetrics and Gynecology
- University of Texas Southwestern Medical School
- Texas Health Sciences Center
- Dallas, Texas

Mitchell S. Golbus, M.D
- Associate Professor of Obstetrics and Gynecology and Pediatrics
- University of California School of Medicine
- San Francisco, California

Albert R. Jonsen, Ph.D
- Associate Professor of Bioethics
- University of California School of Medicine
- San Francisco, California

Maurice J. Mahoney, M.D
- Associate Professor of Pediatrics and Human Genetics
- Yale University School of Medicine
- New Haven, Connecticut

Godfrey Oakley, M.D
- Chief, Birth Defects Branch
- Chronic Disease Division
- Bureau of Epidemiology
- Center for Disease Control
- Atlanta, Georgia

Norman Scotch, Ph.D
- Professor and Chairman
- Department of Sociomedical Sciences and Community Medicine
- Professor of Anthropology
- Boston University School of Medicine
- Boston, Massachusetts

J. Michael Swint, Ph.D
- Associate Professor of Economics
- University of Texas Health Sciences Center at Houston
- School of Public Health
- Houston, Texas

Elaine Whitelaw
- Special Assistant to the President
- National Foundation--March of Dimes
- White Plains, New York

Laeitia Wotta
- Task Force Assistant
- Harbor-UCLA Medical Center
- Torrance, California

## Task Force on Predictors of Fetal Maturation

Joseph Dancis, M.D. (Chairman)
- Professor and Chairman
- Department of Pediatrics
- New York University School of Medicine

Randall Bloomfield, M.D
- Director
- Department of Obstetrics and Gynecology
- Kings County Hospital Center

Paul Feeley, O. Carm
- Chairman
- Health Systems Agency
- District C, Manhattan

Louis Gluck, M.D
- Professor of Pediatrics
- School of Medicine
- University of California, San Diego

John Hobbins, M.D
- Professor of Obstetrics and Gynecology
- Yale University School of Medicine

Angela R. Holder, LL.M
- Counsel for Medicolegal Affairs
- Assistant Clinical Professor of Pediatrics (LAW)
- Yale-New Haven Hospital

Rudy Sabbagha, M.D
- Associate Professor of Obstetrics and Gynecology
- Director, Ultrasound Laboratory
- Prentice Women's Hospital
- Northwestern University Medical School

James Sorenson, Ph.D
- Associate Professor
- Department of Sociomedical Sciences and Community Medicine
- Boston University School of Medicine

Philip Sunshine, M.D
- Professor of Pediatrics
- Stanford University
- School of Medicine

Bruce Young, M.D
- Associate Professor of Obstetrics and Gynecology
- Director, Division of Maternal-Fatal Medicine
- New York University School of Medicine

## Task Force on Predictors of Fetal Distress

Frederick P. Zuspan, M.D
- Task Force Chairman
- Professor and Chairman
- Department of Obstetrics and Gynecology
- The Ohio State University College of Medicine
- Columbus, Ohio

Lawrence Chik, Ph.D
- Assistant Professor
- Department of Reproductive Biology
- Case Western Reserve University
- Department of Obstetrics and Gynecology
- Cleveland Metropolitan General Hospital
- Cleveland, Ohio

Bradford Gray, Ph.D
- Professional Associate
- Institute of Medicine
- Washington, DC

L. Stanley James, M.D
- Professor of Pediatrics
- Columbia Presbyterian Medical Center
- New York, New York

Barbara Katz, J.D
- Deputy General Counsel
- Massachusetts Department of Public Health
- Boston, Massachusetts

Phyllis Leppert, R.N., C.N.M., M.D
- Department of Obstetrics and Gynecology
- Yale-New Haven Hospital
- New Haven, Connecticut

Raymond R. Neutra, M.D., Dr. P.H
- Associate Professor
- Division of Epidemiology UCLA School of Public Health
- Los Angeles, California

Nigel Paneth, M.D., Ph.D
- Assistant Professor of Public Health and Pediatrics
- Gertrude H. Sergievsky Center
- Columbia University
- New York, New York

Tabitha M. Powledge, M.S
- Research Associate for Genetics
- Institute of Society, Ethics, and the Life Sciences
- Hastings-on-Hudson, New York

Edward J. Quilligan, M.D
- Associate Vice President for Health Affairs
- Professor of Obstetrics and Gynecology
- University of Southern California School of Medicine
- Los Angeles, California

Mortimer G. Rosen, M.D
- Professor
- Department of Reproductive Biology
- Case Western Reserve University
- Director of Department of Obstetrics and Gynecology
- Cleveland Metropolitan General Hospital
- Cleveland, Ohio

Ama Saran, M.S.W
- Assistant to the Director
- Black Child Development Institute
- Washington, DC

Benjamin Silverman, M.D
- Pediatrician
- Princeton, New Jersey

Judith Wagner, Ph.D
- Senior Research Associate
- Urban Institute
- Washington, DC

## Conference Sponsors

- National Institute of Child Health and Human Development
- Fogarty International Center, NIH
- Office of Medical Applications of Research, NIH