# Geriatric Assessment Methods for Clinical Decision Making

National Institutes of Health Consensus Development Conference Statement October 19-21, 1987

## Introduction

The population of elderly persons in the developed nations is growing with extraordinary rapidity. Although the majority enjoy good health, many older people suffer from multiple illnesses and significant disability. Comprehensive assessment methodologies, while not solely applicable to frail elderly persons, are believed to be particularly suited to their situation. These individuals tend to exhibit great medical complexity and vulnerability; have illnesses with atypical and obscure presentations; suffer major cognitive, affective, and functional problems; are especially vulnerable to iatrogenesis; are often socially isolated and economically deprived; and are at high risk for premature or inappropriate institutionalization.

To deal with the exceedingly difficult health care issues posed by frail elderly persons, health professionals need to collect, organize, and use a vast array of clinically relevant information. This process, comprehensive geriatric assessment, is defined as a multidisciplinary evaluation in which the multiple problems of older persons are uncovered, described, and explained, if possible, and in which the resources and strengths of the person are catalogued, need for services assessed, and a coordinated care plan developed to focus interventions on the person's problems.

Comprehensive geriatric assessment generally includes evaluation of the patient in several domains, most commonly the physical, mental, social, economic, functional, and environmental.

The term "functional" is used here in a narrow sense: It means the ability to function in the arena of everyday living. The panel recognizes that the same word has been used in the much broader sense of the whole range of functions we have listed just above. In other words, some use "functional assessment" to mean what we have termed "comprehensive geriatric assessment."

When applied to clinical decision making, comprehensive geriatric assessment involves clinicians from the many health care professions who are necessarily involved in good geriatric care. Comprehensive geriatric assessment is only one component of general geriatric care. Appropriate geriatric care involves some level of assessment of the multiple domains just cited, but comprehensive geriatric assessment tends to be applied only to a subset of older persons who are frail and considered most likely to benefit (see question 3). It has been suggested that a new form of comprehensive assessment could be developed to evaluate physical fitness for purposes of monitoring health promotion and disease prevention in well older persons and another form to guide the humane care of irreversibly disabled and terminally ill older persons.

Between 1973 and 1987, reports have appeared on a significant number of true experiments exploring the elements and effectiveness of various approaches to geriatric assessment. The data from these studies, coupled with the growing numbers of frail elderly individuals, the high cost of their health care, the intensity of their distress and discomfort, and the great uncertainty as to the best route to wise clinical decision making, led to the current conference. The National Institute on Aging and the Office of Medical Applications of Research of the National Institutes of Health, in conjunction with the National Institute of Mental Health, the Veterans Administration, and the Henry J. Kaiser Family Foundation, convened the Consensus Development Conference on Geriatric Assessment Methods for Clinical Decision making on October 19-21, 1987. After a day and a half of presentations by experts in the field, a consensus panel including methodologists and representatives of medicine, nursing, social work, and the public considered the scientific evidence and developed answers to the following central questions:

1. What are the goals, structure, processes, and elements of geriatric assessment for clinical decision making?
2. What are the comparative merits of different methods in carrying out a geriatric assessment?
3. What is the evidence that a geriatric assessment is effective? If so, in what settings, for whom, and for which outcomes?
4. Insofar as a geriatric assessment is effective, what linkages to clinical management systems are required?
5. What are the priorities for future research in geriatric assessment?

Comprehensive geriatric assessment has been used for many nonclinical purposes, including research, education, health policy, and administration. This report focuses only on its use for clinical decision making.

## What Are the Goals, Structure, Processes, and Elements of Geriatric Assessment for Clinical Decision Making?

### Goals

The goals of comprehensive geriatric assessment are: (1) to improve diagnostic accuracy, (2) to guide the selection of interventions to restore or preserve health, (3) to recommend an optimal environment for care, (4) to predict outcomes, and (5) to monitor clinical change over time.

### Structure

Comprehensive geriatric assessment may be done in many institutional settings, including acute care, psychiatric, or rehabilitation hospitals and nursing homes, and in ambulatory settings, including outpatient or freestanding clinics, the offices of primary care physicians, or in the patient's home. It often has been applied to elderly persons at critical transition points in their lives, including actual or threatened decline in health and functional status, impending change in living environment, bereavement, or other unusual stress.

### Processes

Comprehensive geriatric assessment is initiated by a referral from one of a number of sources (see question 4). In addition to the patient, the process often includes family members and other important persons in the individual's environment. It is conducted by a core team that consists, at a minimum, of a physician, nurse, and social worker, each with special expertise in caring for older people. Frequently, a psychiatrist is a member of the core team. The specific activities and contributions of each team member may vary considerably, and flexibility in roles may facilitate the assessment process.

The assessment begins with a case-finding approach that utilizes screening instruments and techniques. Based on these initial findings, a more detailed assessment is frequently undertaken. This in-depth assessment often requires the participation of a number of other professions. These may include audiology, clinical psychology, dentistry, nutrition, occupational therapy, optometry, pharmacy, physical therapy, podiatry, speech pathology, and the clergy. Support from other medical disciplines, such as neurology, ophthalmology, orthopedics, physiatry, surgery, and urology, is commonly needed.

Some aspects of geriatric assessment may be provided by self-rating scales completed by the patient or caregivers. Such information may lead to different insights than those obtained through external assessment performed by a member of the health care team.

### Elements

#### Physical Health

A careful history is obtained from the patient and others with significant knowledge of the patient. Special attention is directed to the use of prescription and nonprescription medications and clues to the presence of malnutrition, falling, incontinence, and immobility. Data are gathered on smoking, exercise, alcohol use, immunization status, and sexual function. Also important is information regarding the patient's personal strengths, values, perceived quality of life, acceptability of interventions, and expected outcomes from his or her health care.

A physical examination is performed with emphasis on identification of specific diseases or conditions for which curative, restorative, palliative, or preventive treatment may be available. Special attention is directed toward visual or hearing impairment, nutritional status, and conditions that may contribute to falling or difficulty in ambulation. Laboratory tests and other diagnostic studies are obtained as indicated.

#### Mental Health

Cognitive, behavioral, and emotional status are evaluated. Detection of dementia, delirium, and depression is particularly important. A range of assessment instruments is available for these purposes. For some patients a detailed psychiatric interview, a neurobehavior consultation, or comprehensive neuropsychological testing is indicated.

#### Social and Economic Status

Evaluating the social support network includes identifying present and potential caregivers and assessing their competence, willingness to provide care, and acceptability to the older person. This information may be obtained by questionnaires, structured interviews, or other methods. The degree of caregiver stress and the caregiver's support network also are considered.

Areas of special importance to the individual, such as cultural, ethnic, and spiritual values, are noted. The individual's own assessment of the quality of life is recorded. The clinician evaluates the economic resources of the elderly person, which often determine access to medical and personal care and influence options for living arrangements.

#### Functional Status

There are several components to a comprehensive assessment of an older person's ability to function. Physical functioning usually is measured by the ability to accomplish basic activities of daily living (ADL), including bathing, dressing, toileting, transferring, continence, and feeding.

Other components of functional well-being are behavioral and social activities that require a higher level of cognition and judgment than physical activities. These instrumental activities of daily living (IADL) include preparation of meals, shopping, light housework, financial management, medication management, use of transportation, and use of the telephone.

Functional status (ADL and IADL) is probably most accurately evaluated by direct observation of the patient by family or health professionals in the home or a simulated homelike environment. However, surprisingly accurate information is also obtained by standardized questionnaire or self-report.

#### Environmental Characteristics

Evaluating the patient's physical environment is essential. Home visits and questionnaires are used to determine the safety, physical barriers, and layout of the home as well as access to services, such as shopping, pharmacy, transportation, and recreation.

### Development and Implementation of a Care Plan

Comprehensive geriatric assessment is a dynamic, ongoing process. After the initial assessment, the team generates a comprehensive list of the patient's needs and strengths, usually at a multidisciplinary case conference. Recommendations are integrated into an individualized plan of interventions and desired outcomes. The preferences of the patient and family must be especially carefully considered at this stage in the process. If the assessment takes place in an inpatient facility, treatment and rehabilitation are often initiated in that facility, sometimes directly by members of the team on a specialized unit. In consultative models, the team's recommendations are transmitted to the appropriate primary care providers. Regardless of the site of assessment or the primary responsibility for implementation of the recommended regimen, periodic reassessment and appropriate modification of the care plan are central elements of the process of comprehensive geriatric assessment.

## What Are the Comparative Merits of Different Methods in Carrying Out a Geriatric Assessment?

Many assessment methods for specific domains have undergone rigorous validation, and the criteria for acceptance of a given method have been carefully defined. However, in domains in which there are multiple validated instruments to measure the same function, there have not yet been studies that directly compare one method to another. As a result, identification of the single best instrument in each domain is not possible at this time. One of the first steps in establishing a program of geriatric assessment is deciding upon a standardized approach to data collection. Before choosing from among the different methods, clinicians should consider some of the following issues.

In the context of comprehensive geriatric assessment, there is a role for both structured and unstructured methods of data gathering. There are several merits of a structured approach. Precision, reproducibility, and freedom from bias are enhanced by using standardized validated questions and requiring the respondent to choose from a limited number of answers. The task of data collection is more easily delegated if the format is standardized. Standardized data collection methods help in clinical decision making and prospective evaluation of the efficacy of interventions. On the other hand, merits of unstructured methods include flexibility of the testing procedure, ability to probe problems in detail, and the opportunity for synthesis of findings to develop a global impression.

A number of assessment instruments have been shown individually to have good reliability and validity. A reliable instrument is internally consistent and provides the same evaluation of the patient when used by different raters. A valid instrument measures correctly the domain being investigated. In addition to quantitatively measured validity and reliability, an instrument should have face validity (i.e., on the "face of it" the instrument appears to measure the domain correctly). Although some characteristics of patients who will benefit from a given type of assessment have been identified, there are no validated instruments for predicting benefit.

One approach to developing a comprehensive geriatric assessment program is to select one of several multidimensional instruments designed to address all major domains of geriatric assessment. Alternatively, specific assessment instruments developed for each domain can be combined to accomplish a comprehensive assessment. There is no evidence that either approach is superior to the other.

Desirable characteristics of instruments for case finding are efficiency, simplicity, flexibility for use under a variety of circumstances, and portability. Case-finding requires less sophistication from the examiner than in-depth assessment and is relatively inexpensive. There are reliable and valid instruments with which to assess mental function, socioeconomic status, and ADL. Each instrument has a specific range of usefulness. For example, assessment of ADL reliably detects advanced degrees of functional impairment but is quite unlikely to detect minimal departures from normalcy.

In-depth geriatric assessment methods need to have high predictive value, detect small changes in function, identify potentially remediable problems, and efficiently predict patient outcomes. Special expertise is often required to carry out an in-depth assessment.

Three additional issues should be addressed. First, in-depth assessments (and consequent interventions) must take patients' values into account. Second, comprehensive assessment methods should accurately reflect change in patient status over time. Most existing methods do not meet this need. Finally, while it is possible to educate a variety of health care professionals to carry out various aspects of comprehensive assessment, experience and leadership are required in the individual or individuals responsible for supervising the assessment effort.

## What Is the Evidence That a Geriatric Assessment Is Effective? If So, in What Settings, for Whom, and for Which Outcomes?

Accumulated evidence indicates with moderate-to-high confidence that comprehensive geriatric assessment is effective when coupled with ongoing implementation of the resulting care plan.

The settings in which effectiveness has been convincingly demonstrated are the combined geriatric assessment and rehabilitation unit and the inpatient geriatric assessment unit. There is less consistent evidence regarding the effectiveness of comprehensive geriatric assessment in the home, ambulatory setting, and the hospital inpatient consultation service.

As practiced, comprehensive geriatric assessment has been demonstrated to be effective for a variety of desirable outcomes. Studies to test effectiveness have varied in design from descriptive (before versus after) to match control to the most persuasive form, randomized controlled trials.

Outcomes favorably affected by comprehensive geriatric assessment, as demonstrated by randomized controlled trials, have included improved diagnostic accuracy, prolonged survival, reduced annual medical care costs, reduced use of acute hospitals, and reduced nursing home use. These have been most consistently demonstrated. Less consistently reported benefits include increased use of health and social services delivered in the home, reduced medications, and improved placement location, affect and cognition, and functional status. Other outcomes of great importance (e.g., quality of life) have not been studied adequately.

Two aspects of comprehensive geriatric assessment appear to be of central importance. The first of these is targeting of the process to those persons most likely to benefit, a feature of most successful programs and one strongly endorsed by experienced program leaders. In the inpatient setting, targeting has focused on patients over age 75 and those with potentially reversible disabilities. This target group may account for as much as 10 to 25 percent of hospitalized elderly patients. Most studies demonstrating effectiveness have excluded groups whom the investigators thought least likely to benefit, notably persons who are fully independent and those with end-stage disease or disability. Several programs have focused on elderly persons at points of transition or instability, as cited under question 1.

The role of targeting in comprehensive geriatric assessment conducted outside the hospital setting is less clear. Certain U.S. studies have failed to demonstrate favorable outcomes in ambulatory settings. This result may be attributable to ineffective targeting. However, two European studies of randomly selected, community-dwelling persons reported efficacy of comprehensive geriatric assessment without targeting other than for advanced age, suggesting the possibility of expanding the use of these techniques to a broader population in this country.

The second important aspect of comprehensive geriatric assessment appears to be the link between assessment and followup services (also discussed under question 4). Successful programs have been able to assure adoption of treatment recommendations reached during the initial assessment. In some programs, the assessment team has assumed direct control over treatment of the patients, while in others the followup has involved active and ongoing consultation and communication with primary care providers. The failure to provide sufficient linkage between assessment and followup may provide another explanation for negative results reported in certain studies. In addition, these negative results may be due to an insufficiently comprehensive assessment or intervention (e.g., failure to include medical evaluation) or to the use of instruments insensitive to changes that actually may have occurred.

Additional elements of the comprehensive geriatric assessment to which effectiveness has been attributed by developers of successful programs deserve attention. Such elements include focus upon content areas in which geriatric expertise is acknowledged: malnutrition, mental impairment, immobility, iatrogenesis (notably polypharmacy), impaired homeostasis, and incontinence. Furthermore, the effectiveness of the comprehensive geriatric assessment appears to be more than the sum of its parts, perhaps because of the integrative nature of the process and the multidisciplinary discussion that translates the information gathered into a rational plan of care. Finally, it has also been suggested that the effectiveness of comprehensive geriatric assessment is at least partly attributable to the enthusiasm and caring attitude of those who have developed these programs.

## Insofar as a Geriatric Assessment Is Effective, What Linkages to Clinical Management Systems Are Required?

Comprehensive geriatric assessment programs should not be viewed as operating independently from other elements of the health care system. Geriatric assessment is a dynamic process responsive to the changes in health status that occur over time. Therefore, a method for assessing effectiveness of interventions over time and for detecting new problems must be provided. A broad approach is needed to ensure that community case-finding identifies the at-risk population and links comprehensive geriatric assessment to subsequent provision of services.

In the absence of a community case-finding program, patients are referred for comprehensive geriatric assessment from a variety of sources, most commonly relatives and community service agencies. Less common sources of referral are the patients themselves, friends, and physicians. Health maintenance organizations and other managed care organizations, as well as nursing homes, may be increasingly important referral sources in the future.

Ongoing monitoring of the implementation of recommendations made during comprehensive geriatric assessment is believed to be central to the success of the care plan. The role of linkages to clinical management systems in the effectiveness of comprehensive geriatric assessment has not been directly tested. However, continuing personal contact of hospital geriatric assessment consultants with the patients and their primary providers does appear to facilitate the implementation of recommendations. Case management as a process to provide linkages is available in many communities, and its role in ensuring followup of recommendations requires further investigation. Clearly, the availability of a wide array of social services is a requirement for successful implementation of a comprehensive geriatric care plan.

## What Are the Priorities for Future Research in Geriatric Assessment?

Although past research on comprehensive geriatric assessment has provided much valuable information, many questions remain unanswered. Existing studies have demonstrated that effective services can be provided, but these services consist of combinations of activities that have been selected on an empiric basis. Future research can define more carefully which elements of these packages--perhaps all of them--contribute importantly to achieving the observed results. Earlier studies have been site-specific and have incompletely assessed the range of patients who might benefit from these activities. Finally, important measurement problems persist. Thus, key future steps in research include the following:

- Conduct multicenter, randomized controlled trials of comprehensive geriatric assessment, including both academic and nonacademic settings, addressing the above-cited gaps in our knowledge.
- Extend the use of randomized controlled trials of comprehensive geriatric assessment to other outcomes, particularly quality of life, effect on family, and cost-effectiveness.
- Extend the use of randomized controlled trials of comprehensive geriatric assessment to other settings, particularly the home and the nursing home.
- Determine the most effective means for targeting of comprehensive geriatric assessments in a broad patient population.
- Use controlled trials of comprehensive geriatric assessment to evaluate the effect of different combinations of personnel, instruments, and interventions.
- Compare the effects of assessment with and without various methods for coordinated implementation of the care plan.
- Develop new assessment tools for measuring levels of and changes in functional status, particularly for those with mild-to-moderate levels of impairment.
- Directly compare instruments that assess information within the same domain.
- Develop data bases with which to establish patterns of changing function, especially in persons who spend time in long-term care institutions.

## Conclusions

The settings, uses, processes, personnel, and component domains of comprehensive geriatric assessment have been defined with sufficient clarity to provide guidelines for establishment of new assessment programs.

Accumulated evidence indicates with moderate-to-high confidence that comprehensive geriatric assessment is effective when coupled with ongoing implementation of the resulting care plan.

Effectiveness has been most convincingly demonstrated in two inpatient settings, the geriatric assessment unit and the combined geriatric assessment-rehabilitation unit.

The most consistently demonstrated favorable outcomes of comprehensive geriatric assessment have been prolonged survival, reduced annual medical care costs, and reduced use of acute hospitals and nursing homes.

Although the evidence allows for alternative interpretation, it is probable that careful selection of patients has contributed importantly to the ability to demonstrate benefit from comprehensive geriatric assessment.

In view of the seemingly indispensable role of monitoring and implementation of the care plan in achieving desired outcomes, ongoing health care should be linked systematically to the process of comprehensive geriatric assessment.

## Consensus Development Panel

- David H. Solomon, M.D.
- Panel and Conference Chairperson
- Professor of Medicine
- Associate Director
- Multicampus Division of Geriatric Medicine
- University of California at Los Angeles School of
- Medicine
- Los Angeles, California

- A. Sue Brown, M.S.W.
- Administrator
- Long-Term Care Administration
- District of Columbia Department of Human Services
- Commission of Public Health
- Washington, D.C.

- Kenneth Brummel-Smith, M.D.
- Associate Professor of Clinical Family Medicine
- Director
- Section of Geriatrics
- Department of Family Medicine
- University of Southern California
- Co-Chief
- Clinical Gerontology Service
- Rancho Los Amigos Medical Center
- Downey, California

- Lavola Burgess
- Member
- Board of Directors
- American Association of Retired Persons
- Albuquerque, New Mexico

- Ralph B. D'Agostino, Ph.D.
- Chairman
- Mathematics Department
- Professor of Mathematics, Statistics, and Public Health
- Boston University
- Boston, Massachusetts

- John W. Goldschmidt, M.D.
- Medical Director
- National Rehabilitation Hospital
- Washington, D.C.

- Jeffrey B. Halter, M.D.
- Professor of Internal Medicine
- Chief
- Division of Geriatric Medicine
- Medical Director
- Institute of Gerontology
- University of Michigan and Veterans Administration Medical Centers
- Ann Arbor, Michigan

- William R. Hazzard, M.D.
- Chairman and Professor
- Department of Medicine
- Bowman Gray School of Medicine
- Wake Forest University
- Winston-Salem, North Carolina

- Dennis W. Jahnigen, M.D.
- Head
- Section of Geriatric Medicine
- Department of Internal Medicine
- Cleveland Clinic Foundation
- Cleveland, Ohio

- Charles Phelps, Ph.D.
- Professor of Economics and Political Science
- Director
- Public Policy Analysis Program
- University of Rochester
- Rochester, New York

- Murray Raskind, M.D.
- Professor and Vice Chairman for Research and Development
- Department of Psychiatry and Behavioral Sciences
- University of Washington School of Medicine
- Seattle, Washington

- Robert W. Schrier, M.D.
- Professor and Chairman
- Department of Medicine
- University of Colorado School of Medicine
- Denver, Colorado

- Harold C. Sox, Jr., M.D.
- Professor of Medicine
- Division of General Internal Medicine
- Stanford University School of Medicine
- Stanford, California

- Sankey V. Williams, M.D.
- Associate Professor of Medicine
- Section of General Medicine
- Leonard Davis Institute of Health Economics
- University of Pennsylvania School of Medicine
- Philadelphia, Pennsylvania

- May Wykle, Ph.D., R.N., F.A.A.N.
- Professor and Chairperson
- Psychiatric/Mental Health Nursing and Gerontological Nursing
- Frances Payne Bolton School of Nursing
- Case Western Reserve University
- Cleveland, Ohio

## Speakers

- Toni C. Antonucci, Ph.D.
- "Qualitative Aspects of Social Supports, Personal Resources, and Environment: Implications for Health Care Providers"
- Associate Research Scientist
- Institute for Social Research
- Assistant Professor
- University of Michigan School of Medicine
- Ann Arbor, Michigan

- William B. Applegate, M.D., M.P.H.
- "A Hospital-Based Geriatric Assessment Unit"
- Professor of Medicine and Preventive Medicine
- University of Tennessee at Memphis
- Memphis, Tennessee

- Ronald D. Bayne, M.D., F.R.C.P.(C), F.A.C.P.
- "Canadian Models of Geriatric Assessment"
- Professor of Medicine (Gerontology)
- McMaster University
- Hamilton, Ontario
- CANADA

- Lisa F. Berkman, Ph.D.
- "Social Networks and Social Support: Moving Towards an Appropriate Geriatric Assessment"
- Associate Professor of Epidemiology
- Yale University School of Medicine
- New Haven, Connecticut

- Richard W. Besdine, M.D.
- "General Medical Evaluation"
- Travelers Professor of Geriatrics and Gerontology Director
- Travelers Center on Aging
- University of Connecticut Health Center School of
- Medicine
- Farmington, Connecticut

- Dan G. Blazer II, M.D., Ph.D.
- "Assessment of Cognitive and Behavioral Status"
- Professor of Psychiatry
- Director
- Affective Disorders Program
- Duke University Medical Center
- Durham, North Carolina

- Edward W. Campion, M.D.
- "Geriatric Inpatient Consultation"
- Chief
- Geriatrics Unit
- Massachusetts General Hospital
- Boston, Massachusetts

- Leo M. Cooney, Jr., M.D.
- "Geriatric Assessment in the Long-Term Care Setting"
- Professor of Medicine
- Yale University School of Medicine
- New Haven, Connecticut

- Gerald M. Eggert, Ph.D.
- "The Evolution of a Communitywide Assessment System"
- Executive Director
- Monroe County Long-Term Care Program, Inc./ACCESS
- East Rochester, New York

- Arnold M. Epstein, M.D.
- "Geriatric Assessment Units for Ambulatory Elderly Patients in a Health Maintenance Organization"
- Assistant Professor of Medicine
- Harvard Medical School
- Member
- Institute for Health Research
- Harvard School of Public Health
- Boston, Massachusetts

- Alvan R. Feinstein, M.D.
- "Summary of Methodology"
- Professor of Medicine and Epidemiology
- Yale University School of Medicine
- New Haven, Connecticut

- Barry J. Gurland, M.D.
- "Comprehensive Geriatric Assessment Instruments"
- John E. Borne Professor of Clinical Psychiatry
- Director
- Center for Geriatrics and Gerontology
- Columbia University
- New York, New York

- Sidney Katz, M.D.
- "Functional Assessment in Geriatrics"
- Professor of Bio-architectonics
- Bio-architectonics Center
- Case Western Reserve University School of Medicine
- Cleveland, Ohio

- M. Powell Lawton, Ph.D.
- "Behavioral and Social Components of Functional Capacity"
- Director of Research
- Philadelphia Geriatric Center
- Philadelphia, Pennsylvania

- Michael A. Nevins, M.D.
- "Report on American College of Physicians Meeting on Geriatric Assessment"
- Chairman
- Subcommittee on Aging
- American College of Physicians
- Rivervale, New Jersey

- Barbara R. Phillips, Ph.D.
- "Geriatric Assessment in the National Long-Term Care Channeling Demonstration"
- Senior Researcher
- Mathematica Policy Research
- Princeton, New Jersey

- Laurence Z. Rubenstein, M.D., M.P.H.
- "Hospital-Based Geriatric Assessment: The Sepulveda Veterans Administration Geriatric Evaluation Unit"
- Associate Professor of Medicine
- University of California at Los Angeles School of
- Medicine
- Clinical Director
- GRECC
- Veterans Administration Medical Center
- Sepulveda, California

- Knight Steel, M.D.
- "The Home as a Model Setting for Geriatric Assessment"
- Professor of Medicine
- Boston University
- Boston, Massachusetts

- Mark E. Williams, M.D.
- "Outpatient Geriatric Assessment"
- Assistant Professor of Medicine
- Department of Medicine
- University of North Carolina at Chapel Hill
- Chapel Hill, North Carolina

- T. Franklin Williams, M.D.
- "Historical Perspective: Comprehensive Geriatric Assessment"
- Director
- National Institute on Aging
- National Institutes of Health
- Bethesda, Maryland

- Carol Hutner Winograd, M.D.
- "The Inpatient Model of Geriatric Consultation"
- Assistant Professor of Medicine (Gerontology)
- Stanford University
- Director of Clinical Activities
- Geriatric Research, Education, and Clinical Center
- Veterans Administration Medical Center
- Pal Alto, California

## Planning Committee

- Knight Steel, M.D.
- Planning Committee Cochairperson
- Professor of Medicine
- Boston University
- Boston, Massachusetts

- T. Franklin Williams, M.D.
- Planning Committee Cochairperson
- Director
- National Institute on Aging
- National Institutes of Health
- Bethesda, Maryland

- William B. Applegate, M.D., M.P.H.
- Professor of Medicine and Preventive Medicine
- University of Tennessee at Memphis
- Memphis, Tennessee

- Shirley P. Bagley
- Assistant Director for Special
- Programs
- National Institute on Aging
- National Institutes of Health
- Bethesda, Maryland

- Michael J. Bernstein
- Director of Communications
- Office of Medical Applications of Research
- National Institutes of Health
- Bethesda, Maryland

- Gene D. Cohen, M.D., Ph.D.
- Director
- Program on Aging
- National Institute of Mental Health
- National Institutes of Health
- Rockville, Maryland

- Jerry M. Elliott
- Program Analyst
- Office of Medical Applications of Research
- National Institutes of Health
- Bethesda, Maryland

- Marsha E. Goodwin, R.N.-C., M.A., M.S.N.
- Chief
- Education and Training in Geriatrics
- Veterans Administration
- Washington, D.C.

- Evan C. Hadley, M.D.
- Chief
- Geriatrics Branch
- Biomedical Research and Clinical Medicine Program
- National Institute on Aging
- National Institutes of Health
- Bethesda, Maryland

- Claire McCullough
- Public Affairs Specialist
- Public Information Office
- National Institute on Aging
- National Institutes of Health
- Bethesda, Maryland

- Edwin Olsen, M.D.
- Assistant Chief Medical Director
- Geriatrics and Extended Care
- Veterans Administration
- Washington, D.C.

- Lot B. Page, M.D.
- Assistant Director for International Activities
- National Institute on Aging
- National Institutes of Health
- Bethesda, Maryland

- L. Gregory Pawlson, M.D., M.P.H.
- Director
- Center for Aging Studies and Services
- George Washington University
- Medical Center
- Washington, D.C.

- Martin Rose, M.D.
- Former Chief Medical Officer
- Office of Medical Applications of Research
- National Institutes of Health
- Bethesda, Maryland

- David H. Solomon, M.D.
- Panel and Conference Chairperson
- Professor of Medicine
- Associate Director
- Multicampus Division of Geriatric Medicine
- University of California at Los Angeles
- School of Medicine
- Los Angeles, California

## Conference Sponsors

- National Institute on Aging
- T. Franklin Williams, M.D.
- Director

- National Institute of Mental Health
- Frank J. Sullivan, Ph.D.
- Acting Director

- Veterans Administration
- Thomas K. Turnage
- Administrator

- Henry J. Kaiser Family Foundation
- Alvin R. Tarlov, M.D.
- President

- NIH Office of Medical Applications of Research
- William T. Friedewald, M.D.
- Acting Director