# Optimal Calcium Intake

National Institutes of Health Consensus Development Conference Statement June 6-8, 1994

The National Institutes of Health Consensus Development Conference on Optimal Calcium Intake brought together experts from many different fields including osteoporosis and bone and dental health, nursing, dietetics, epidemiology, endocrinology, gastroenterology, nephrology, rheumatology, oncology, hypertension, nutrition and public education, and biostatistics, as well as the public to address the following questions: (1) What is the optimal amount of calcium intake? (2) What are the important cofactors for achieving optimal calcium intake? (3) What are the risks associated with increased levels of calcium intake? (4) What are the best ways to attain optimal calcium intake? (5) What public health strategies are available and needed to implement optimal calcium intake recommendations? and (6) What are the recommendations for future research on calcium intake?

The consensus panel concluded that

- A large percentage of Americans fail to meet currently recommended guidelines for optimal calcium intake.
- On the basis of the most current information available, optimal calcium intake is estimated to be 400 mg/day (birth 6 months) to 600 mg/day (6 12 months) in infants; 800 mg/day in young children (1 5 years) and 800 1,200 mg/day for older children (6 10 years); 1,200 1,500 mg/day for adolescents and young adults (11 24 years); 1,000 mg/day for women between 25 and 50 years; 1,200 1,500 mg/day for pregnant or lactating women; and 1,000 mg/day for postmenopausal women on estrogen replacement therapy and 1,500 mg/day for postmenopausal women not on estrogen therapy. Recommended daily intake for men is 1,000 mg/day (25 65 years). For all women and men over 65, daily intake is recommended to be 1,500 mg/day, although further research is needed in this age group. These guidelines are based on calcium from the diet plus any calcium taken in supplemental form.
- Adequate vitamin D is essential for optimal calcium absorption. Dietary constituents, hormones, drugs, age, and genetic factors influence the amount of calcium required for optimal skeletal health.
- Calcium intake, up to a total intake of 2,000 mg/day, appears to be safe in most individuals.
- The preferred source of calcium is through calcium-rich foods such as dairy products. Calcium-fortified foods and calcium supplements are other means by which optimal calcium intake can be reached in those who cannot meet this need by ingesting conventional foods.
- A unified public health strategy is needed to ensure optimal calcium intake in the American population.

The full text of the consensus panel's statement follows.

## Introduction

It has been a decade since the 1984 Consensus Development Conference on Osteoporosis first suggested that increased intake of calcium might help prevent osteoporosis. Osteoporosis affects more than 25 million people in the United States and is the major underlying cause of bone fractures in postmenopausal women and the elderly. Previous surveys have revealed that the U.S. population experiences more than 1.5 million fractures annually at a cost in excess of $10 billion per year to the health care system. Two important factors that influence the occurrence of osteoporosis are optimal peak bone mass attained in the first two to three decades of life and the rate at which bone is lost in later years. Adequate calcium intake is critical to achieving optimal peak bone mass and modifies the rate of bone loss associated with aging. A number of publications have addressed the possible role of calcium intake in the prevention of disorders other than osteoporosis, including other bone diseases, oral bone loss, colon cancer, hypertension, and preeclampsia, a hypertensive disorder of pregnancy. The results of recent research investigating these issues indicate that the optimal amount of calcium intake may be greater than the amount consumed by most Americans. At the same time, the general public and scientists have been exposed to a body of information emphasizing the value of ensuring adequate calcium intake throughout life.

Calcium is an essential nutrient. Optimal calcium intake may vary according to a person's age, sex, and ethnicity. Other factors play a role in calcium intake, including vitamin D, which is needed for adequate calcium absorption. Many factors can negatively influence calcium availability, such as certain medications or food components. Optimal calcium intake may be achieved through diet, calcium-fortified foods, calcium supplements, or various combinations of these.

In view of the great public interest in nutrition and disease prevention, the scientific community has an obligation to integrate new data and to provide health care practitioners and the public with guidance, even though all of the necessary long-term studies may not have been completed. In some cases, the new data, however exciting, point to the need for further research rather than to specific recommendations. Future investigations in this rapidly expanding area of research will lead undoubtedly to more definitive information, which will provide the basis for new recommendations.

To address issues related to optimal calcium intake, the National Institute of Arthritis and Musculoskeletal and Skin Diseases together with the Office of Medical Applications of Research of the National Institutes of Health, convened a Consensus Development Conference on Optimal Calcium Intake on June 6-8, 1994. The conference was cosponsored by the Office of Research on Women's Health, Office of the Director; the National Institute on Aging; the National Cancer Institute; the National Institute of Child Health and Human Development; the National Institute of Diabetes and Digestive and Kidney Diseases; the National Heart, Lung, and Blood Institute; and the National Institute of Dental Research, all of the National Institutes of Health. Conference participants included experts from many different fields, including osteoporosis and bone and dental health, nursing, dietetics, epidemiology, endocrinology, gastroenterology, nephrology, rheumatology, oncology, hypertension, nutrition and public education, and biostatistics, as well as representatives from the public.

After 1-1/2 days of presentations by experts in the relevant fields and audience discussion, an independent, non-Federal consensus panel weighed the scientific evidence and formulated a consensus statement in response to the following six questions:

- What is the optimal amount of calcium intake?
- What are the important cofactors for achieving optimal calcium intake?
- What are the risks associated with increased levels of calcium intake?
- What are the best ways to attain optimal calcium intake?
- What public health strategies are available and needed to implement optimal calcium intake recommendations?
- What are the recommendations for future research on calcium intake?

The consensus panel prepared a draft report summarizing the evidence pertinent to the key issues regarding optimal calcium intake.

## 1. What Is the Optimal Amount of Calcium Intake?

Calcium is a major component of mineralized tissues and is required for normal growth and development of the skeleton and teeth. Optimal calcium intake refers to the levels of consumption that are necessary for an individual (a) to maximize peak adult bone mass, (b) to maintain adult bone mass, and (c) to minimize bone loss in the later years.

Calcium requirements vary throughout an individual's lifetime, with greater needs during the periods of rapid growth in childhood and adolescence, during pregnancy and lactation, and in later adult life (see Table 1). Because 99 percent of total body calcium is found in bone, the need for calcium is largely determined by skeletal requirements. Most studies examining the efficacy of calcium intake on bone mass have used measures of external calcium balance and bone densitometry as primary outcomes. The results of balance studies suggest a threshold effect for calcium intake: Body retention of calcium increases with increasing calcium intake up to a threshold, beyond which further calcium intake causes no additional increment in calcium retention.

Table 1. Optimal Calcium Requirements

Group | Optimal Daily Intake (in mg of calcium)
Infant
Birth-6 months | 400
6 months-1 year | 600
Children
1-5 years | 800
6-10 years | 800-1,200
Adolescents/Young Adults
11-24 years | 1,200-1,500
Men
25-65 years | 1,000
Over 65 years | 1,500
Women
25-50 years | 1,000
Over 50 years (postmenopausal) | 1,500
On estrogens | 1,000
Not on estrogens | 1,500
Over 65 years | 1,500
Pregnant and nursing | 1,200-1,500

A great deal of recent data related to calcium intake and its effects on calcium balance, bone mass, and the prevention of osteoporosis was reviewed, with attention given to the calcium requirements over the life cycle. The current Recommended Dietary Allowances(RDA) (10th edition, 1989) for calcium intake were considered as reference levels and used as guidelines to determine optimal calcium intake in light of new data on calcium-related disorders.

### Infants (Birth-12 Months) and Young Children (1-10 Years)

Calcium intake of exclusively breast-fed infants during the first 6 months of life is in the range of 250-330 mg/day, with a fractional calcium absorption between 55 and 60 percent. A lower fractional absorption of 40 percent is found with cow milk-based formulas. These formulas contain nearly twice the calcium content of human milk; this results in comparable calcium retentions of 150-200 mg/day from both formula and breast milk. Net calcium absorption from soy-based formulas is comparable to, or higher than, that of breast milk or cow milk formulas because of its considerably higher calcium content. For infants between the ages of 6 and 12 months, calcium intake ranges from 400 to 700 mg/day. On the basis of balance data, the current RDAs for calcium, 400 mg/day for infants from birth to 6 months and 600 mg/day for those from 6 to 12 months, seem sufficient to provide optimal calcium intake. However, special circumstances such as low birth weight may require higher calcium intake.

Limited data from one recent study suggest that in children 6-10 years old, intake above 800 mg/day may lead to increased rates of bone accumulation. Coupled with calcium balance data, this suggests that an intake of greater than 800 mg/day may be optimal for this age group. It should also be noted that poor calcium nutrition in childhood may be related to development of enamel hypoplasia and accelerated dental caries.

### Children and Young Adults (11-24 Years)

Calcium accumulation in bone during preadolescence is between 140 and 165 mg/day and may be as high as 400-500 mg/day in the pubertal period. Fractional intestinal absorption is very efficient and estimated to be approximately 40 percent. Peak adult bone mass, depending on the skeletal site examined, is largely achieved by 20 years of age, although important additional bone mass may accumulate through the third decade of life. Furthermore, cross-sectional studies reveal a small but positive association between life-long calcium intake and adult bone mass. Therefore, optimal calcium intake in childhood and young adulthood is critical to achieving peak adult bone mass.

Recent evidence suggests that adding 500-1,000 mg/day to current calcium intake may, at least temporarily, increase bone accretion rates in preadolescent boys and girls. With this supplementation, total calcium intake in these studies exceeded the current RDA of 1,200 mg/day; however, it is unclear whether the effect on bone accretion rates persists beyond the reported 18-month to 3-year periods of treatment and whether these increased rates of bone formation translate into higher peak adult bone mass. Recent balance studies in adolescents indicate a calcium intake threshold in the range of 1,200-1,500 mg/day.

Collectively, these data suggest that calcium intake in the range of 1,200-1,500 mg/day might result in higher peak adult bone mass. Additional research is necessary, particularly longitudinal, long-term dose-ranging studies of the effects of varying calcium intake on bone mass, to more precisely define optimal calcium intake for this age group. Importantly, population surveys of girls and young women 12-19 years of age show their average calcium intake to be less than 900 mg/day, which is well below the calcium intake threshold. The consequences of low calcium intake during this crucial period of rapid skeletal accrual raise concerns that achievement of optimal peak adult peak bone mass may be seriously compromised. Special education and public measures aimed at improving dietary calcium intake in this age group are essential.

### Calcium Intake in Adults (25-65 Years of Age)

Once peak adult bone mass is reached, bone turnover is stable in men and women such that bone formation and bone resorption are balanced. In women, resorption rates increase and bone mass declines beginning with the fall in estrogen production that is associated with the onset of menopause. The decline in circulating 17-beta-estradiol is the predominant factor in the accelerated bone loss that begins after the onset of menopause and continues for 6-8 years. Unlike hormone replacement therapy, supplemental calcium during this initial phase will not slow the decline in bone mass due to estrogen deficiency. Although the effects of calcium can be shown more clearly in postmenopausal women after the period when the effects of estrogen deficiency are no longer dominant (approximately 10 years after menopause), it is likely that the early postmenopausal years are also an important time to ensure optimal calcium intake. Between 25 and 50 years of age, women who are otherwise healthy should maintain a calcium intake of 1,000 mg/day (Osteoporosis. NIH Consensus Statement 1984 Apr 2-4;5(3):1-6). For postmenopausal women who are receiving estrogen replacement therapy, a calcium intake of 1,000 mg/day is recommended to maintain calcium balance and stabilize bone mass. For postmenopausal women who do not take estrogen, it is estimated that a calcium intake of 1,500 mg/day may limit loss of bone mass, but should not be considered a replacement for estrogen. Therefore, recommended calcium intake for postmenopausal women up to 65 years of age is 1,000 mg/day in conjunction with hormonal replacement and 1,500 mg/day in the absence of estrogen replacement.

Adult men also sustain fractures of the hip and vertebrae, although at a lower frequency than women. In several prospective and cross-sectional studies, hip fracture risk in men has been found to be inversely correlated with calcium intake. Although the data are less extensive in men than in women, the evidence in men suggests that inadequate calcium intake is associated with reduced bone mass and increased fracture risk. Available data, although sparse, indicate an optimal calcium intake among adult men similar to women, namely 1,000 mg/day.

### Calcium Intake in Adults (Older Than 65 years)

In men and women 65 years of age and older, calcium intake of less than 600 mg/day is common. Furthermore, intestinal calcium absorption is often reduced because of the effects of estrogen deficiency in women and the age-related reduction in renal 1,25-dihydroxy vitamin D production. Calcium insufficiency due to low calcium intake and reduced absorption can translate into an accelerated rate of age-related bone loss in older individuals. Among the homebound elderly and persons residing in long-term care facilities, vitamin D insufficiency has been detected and may contribute to reduced calcium absorption. Calcium intake among women later in the menopause, in the range of 1,500 mg/day, may reduce the rates of bone loss in selected sites of the skeleton such as the femoral neck. (These findings also indicate that the calcium threshold for reducing bone loss may vary for different regions of the skeleton.)

The physiology of calcium homeostasis in aging men over 65 is similar to that of women with respect to the rate of bone loss, calcium absorption efficiency, declining vitamin D levels, and changes in markers of bone metabolism. It seems reasonable, therefore, to conclude that in aging men, as in aging women, prevailing calcium intakes are insufficient to prevent calcium-related erosion of bone mass.

Thus, in women and in men over 65, calcium intake of 1,500 mg/day seems prudent.

### Pregnant and Lactating Women

The current RDA for calcium intake during pregnancy and lactation is 1,200 mg/day. Pregnancy represents a significant physiological stress on maternal skeletal homeostasis. A full-term infant accumulates approximately 30 grams of calcium during gestation, most of which is assimilated into the fetal skeleton during the third trimester. Available data suggest that, with pregnancy, no permanent decline in body calcium occurs if recommended levels of dietary calcium intake are maintained. There is no association between parity and bone mass. Furthermore, there is no evidence to support changing the current recommendation of calcium intake for well-nourished pregnant women. There is, however, a large population of pregnant women who are not ingesting sufficient calcium, especially those who are undernourished. These women need to be identified, and appropriate adjustments in their calcium intake should be made. Data are not available regarding the calcium requirement for pregnant women at the extremes of reproductive years, for those who experience nonsingleton births, and for those with closely spaced pregnancies.

During lactation, 160-300 mg/day of maternal calcium is lost through production of breast milk. Longitudinal studies in otherwise healthy women demonstrate acute bone loss during lactation that is followed by rapid restoration of bone mass with weaning and the resumption of menses. Women who are lactating should ingest at least 1,200 mg of calcium per day. Lactating adolescents and young adults should ingest up to 1,500 mg of calcium per day.

### Diseases Other Than Osteoporosis

Low calcium intake has been implicated as a determinant of preeclampsia and several other chronic conditions including colon cancer and hypertension. Data regarding the role of supplemental calcium in reducing preeclampsia are conflicting. A large multicenter trial to evaluate this question is under way; the results, which will be available in 1996, should provide the information needed to judge the utility of increased calcium for preeclampsia.

In some recent epidemiological studies, higher calcium intake has been associated with a lower risk for the development of colon cancer. However, the findings are inconsistent, and the number of reports addressing this relationship are limited. Results of short-term clinical trials of the effect of increased calcium intake on rectal mucosal cell proliferation have been mixed and suffer from considerable methodological constraints. Currently, there are insufficient data to establish the role of calcium in colon cancer risk; therefore, a recommendation for increased calcium intake for colon cancer prevention is not warranted at this time.

There are considerable epidemiological and clinical trial data on the relationship between blood pressure levels and calcium intake. Although a number of epidemiological studies suggest an inverse association between blood pressure and calcium intake, most of these studies have been of cross-sectional design, and few prospective studies are available to confirm this association. Results of randomized controlled trials of calcium supplementation on blood pressure have been equivocal. Pooled analyses indicate a small reduction in systolic blood pressure and no effect on diastolic blood pressure. There is speculation that only a subgroup of individuals respond to calcium supplementation; however, randomized trial data are currently not available. A recommendation for increased calcium intake for prevention of hypertension is not warranted at this time, but additional information is needed to identify subpopulations that may benefit from his treatment.

## 2. What Are the Important Cofactors for Achieving Optimal Calcium Intake?

Several cofactors modify calcium balance and influence bone mass. These include dietary constituents, hormones, drugs, and the level of physical activity. Unique host characteristics may also modify the effects of dietary calcium on bone health. These include the individual's age and ethnic and genetic background, the presence of gastrointestinal disorders such as malabsorption and the postgastrectomy syndrome, and the presence of liver and renal disease. Interactions among these diverse cofactors may affect calcium balance in either a positive or negative manner and thus alter the optimal levels of calcium intake.

### Cofactors That Enhance Calcium Absorption

Vitamin D metabolites enhance calcium absorption. 1,25-Dihydroxy vitamin D, the major metabolite, stimulates active transport of calcium in the small intestine and colon. Deficiency of 1,25-dihydroxy vitamin D, caused by inadequate dietary vitamin D, inadequate exposure to sunlight, impaired activation of vitamin D, or acquired resistance to vitamin D, results in reduced calcium absorption. In the absence of 1,25-dihydroxy vitamin D, less than 10 percent of dietary calcium may be absorbed. Vitamin D deficiency is associated with an increased risk of fractures. Elderly patients are at particular risk for vitamin D deficiency because of insufficient vitamin D intake from their diet, impaired renal synthesis of 1,25-dihydroxy vitamin D, and inadequate sunlight exposure, which is normally the major stimulus for endogenous vitamin D synthesis. This is especially evident in homebound or institutionalized individuals. Supplementation of vitamin D intake to provide 600-800 IU/day has been shown to improve calcium balance and reduce fracture risk in these individuals. Sufficient vitamin D should be ensured for all individuals, especially the elderly who are at greater risk for development of a deficiency. Sources of vitamin D, besides supplements, include sunlight, vitamin D-fortified liquid dairy products, cod liver oil, and fatty fish. Calcium and vitamin D need not be taken together to be effective. Excessive doses of vitamin D may introduce risks such as hypercalciuria and hypercalcemia and should be avoided. Anticonvulsant medications may alter both vitamin D and bone mineral metabolism, particularly in certain disorders, in the institutionalized, and in the elderly. Although symptomatic skeletal disease is uncommon in noninstitutionalized settings, optimal calcium intake is advised for persons using anticonvulsants.

Sex hormone deficiency is associated with excessive bone resorption in women and men. Low calcium intake can exacerbate the deleterious consequences of sex hormone deficiency. One study suggested that calcium supplementation can decrease the minimum estrogen dosage required to maintain bone mass in postmenopausal women. However, oral calcium alone does not prevent the postmenopausal bone loss resulting from estrogen deficiency. In addition to estrogen, other endogenous cofactors that could enhance net calcium absorption include growth hormone, insulin-like growth factor-I, and parathyroid hormone.

An interrelationship between physical activity and calcium balance has not been established conclusively. In a single study, increased physical activity enhanced the beneficial effect of oral calcium supplementation on bone mass in young adults. Thus far, studies of elderly individuals and perimenopausal women have failed to establish a positive interaction between calcium intake and exercise to increase bone mass. Therefore, the positive effects of exercise on skeletal health are not likely to be related to calcium intake.

Immobilization has been shown to produce a rapid decrease in bone mass. This loss has been well documented in individuals placed on bed rest and in individuals with regional forms of immobilization such as that seen in para- and quadriplegia. Under these circumstances, the rate of bone loss may be rapid, which is in part related to an increase in bone resorption accompanied by a decrease in bone formation. There is concern that increased calcium intake may increase the risk of hypercalcemia, ectopic calcification, ectopic ossification, and nephrolithiasis in these individuals. Thus, any recommendations for increasing calcium intake are tempered in these individuals by the potential for undesirable consequences.

### Factors That Decrease Calcium Availability

Calcium intake, intestinal absorption, urinary excretion, and endogenous fecal loss influence calcium balance. Intake and absorption account for only 25 percent of the variance in calcium balance, whereas urinary loss accounts for approximately 50 percent. The typical American diet consists of high amounts of sodium and animal protein, both of which can significantly increase urinary calcium excretion. High oxalate and phytate in a limited number of foods can reduce the availability of calcium in these foods. With the exception of large amounts of wheat bran, fiber has not been found to affect calcium absorption significantly. Other dietary components, including fat, phosphate, magnesium, and caffeine, have not been found to affect calcium absorption or excretion significantly. Aluminum in the form of antacid medication, when taken in excess, may significantly increase urinary calcium loss.

Glucocorticoids decrease calcium absorption. States of glucocorticoid excess are associated with negative calcium balance and a marked increase in fracture risk. In a recent study, oral calcium supplements plus 1,25-dihydroxy vitamin D decreased glucocorticoid-associated bone loss. On the basis of these observations and other studies, oral calcium supplements should be considered in all patients who are receiving exogenous glucocorticoids. The specific disease for which the glucocorticoid therapy is used (e.g., rheumatoid arthritis, inflammatory bowel disease, asthma) can be a determining factor in the occurrence and degree of bone loss.

Genetic and ethnic factors significantly influence many aspects of calcium and skeletal metabolism. Twin studies indicate a significant influence of genetic factors on peak bone mass. However, environmental factors appear to be more important in determining rates of bone loss in postmenopausal women. Racial and ethnic differences in bone mass and fracture incidence have been described, but these are not accounted for by differences in calcium intake. Whether there are genetic and ethnic differences in optimal calcium requirements needs to be determined.

## 3. What Are the Risks Associated With Increased Levels of Calcium Intake?

High levels of calcium intake have several potential adverse effects. The efficiency of calcium absorption decreases as intake increases, thereby providing a protective mechanism to lessen the chances of calcium intoxication. This adaptive mechanism can, however, be overcome by a calcium intake of greater than approximately 4 g/day. It is well known that calcium toxicity, with high blood calcium levels, severe renal damage, and ectopic calcium deposition (milk-alkali syndrome), can be produced by overuse of calcium carbonate, encountered clinically in the form of antacid abuse. Even at intake levels less than 4 g/day, certain otherwise healthy persons may be more susceptible to developing hypercalcemia or hypercalciuria. Likewise, subjects with mild or subclinical illnesses marked by dysregulation of 1,25-dihydroxy vitamin D synthesis (e.g., primary hyperparathyroidism, sarcoidosis) may be at increased risk from higher calcium intakes. Nevertheless, in intervention studies (albeit of relatively short duration--less than 4 years), no adverse renal effects of moderate supplementation up to 1,500 mg/day have been reported. Furthermore, one large study suggested that within the current ranges of calcium intake in the population, a higher calcium intake in men is associated with a decreased risk of stone formation. However, a dose-response relationship was not detected. Caution must be used, however, in supplementing individuals who have a history of kidney stones, because high calcium intakes can increase urinary calcium excretion and might increase the risk of stone formation in these patients.

The strategy of increasing calcium intake by increasing dairy products could tend to increase the intake of saturated fat. These potential problems can be averted by the use of low-fat dairy products. Reduced-fat or no-fat dairy products contain as much calcium per serving size as high-fat dairy products. The use of dairy products to increase calcium intake could increase side effects in people who are sensitive to milk products. Nondairy alternative sources are indicated in these individuals.

Concern has been raised that increased calcium intake might interfere with absorption of other nutrients. Iron absorption can be decreased by as much as 50 percent by many forms of calcium supplements or milk ingestion, but not by forms that contain citrate and ascorbic acid, which enhance iron absorption. Thus, increased intakes of specific sources of calcium might induce iron deficiency in individuals with marginal iron status. Population studies suggest that this is not a common or severe problem, but more study is needed. Whether calcium supplements interfere with absorption of other nutrients has not been thoroughly studied. Calcium may also interfere with absorption of certain medications, such as tetracycline.

Gastrointestinal side effects of calcium supplements have been observed, usually at relatively high dosages. A variable effect on the incidence of constipation has been reported in controlled studies of calcium supplements. The calcium ion stimulates gastrin secretion and gastric acid secretion, which can produce a "rebound hyperacidity" when calcium carbonate is used as an antacid. These side effects should not be major problems with a modest increase in calcium intake.

Certain preparations of calcium (e.g., bone meal and dolomite) can have significant contamination with lead and other heavy metals. However, most commercial calcium preparations are tested to ensure that they do not contain significant heavy metal contamination.

In conclusion, a modest increase in calcium intake should be safe for most people. Practices that might encourage total calcium intake to approach or exceed 2,000 mg/day seem more likely to produce adverse effects and should be monitored closely.

## 4. What Are the Best Ways To Attain Optimal Calcium Intake?

The preferred approach to attaining optimal calcium intake is through dietary sources. Additional strategies include the consumption of calcium-fortified foods and calcium supplements. For many Americans, dairy products are the major contributors of dietary calcium because of their high calcium content (e.g., approximately 250-300 mg/8 oz milk) and frequency of consumption. It may be necessary for individuals with lactose intolerance to limit or exclude liquid dairy foods, but adequate calcium intake can be achieved through the use of low-lactose-containing dairy products (solid dairy food) or through milk rendered lactose deficient. Vegans who voluntarily limit their intake of dairy products can obtain dietary calcium through other sources. Other good food sources of calcium include some green vegetables (e.g., broccoli, kale, turnip greens, Chinese cabbage), calcium-set tofu, some legumes, canned fish, seeds, nuts, and certain fortified food products. Breads and cereals, while relatively low in calcium, contribute significantly to calcium intake because of their frequency of consumption.

Recommended calcium intake levels are based on the total calcium content of the food. To maximize calcium absorption, food selection decisions should include information on their bioavailability. Bioavailability (absorption) of calcium from food depends on the food's total calcium content and the presence of components that enhance or inhibit absorption. As mentioned previously, oxalic acid, which is present at high levels in some vegetables (e.g., spinach), has been found to depress absorption of the calcium present in the food but not of calcium in coingested dairy or other calcium-containing foods. Phytic acid also depresses calcium absorption but to a lesser extent. Dietary fiber, except for wheat bran, has little effect on calcium absorption. When present in high concentration, wheat bran has been found to depress calcium absorption from milk.

A number of calcium-fortified food products are currently available, including fortified juices, fruit drinks, breads, and cereals. Although some of these foods provide multiple nutrients and may be frequently consumed, their quantitative contribution and role in the total diet are not currently defined.

For some individuals, calcium supplements may be the preferred way to attain optimal calcium intake. Calcium supplements are available as various salts, and most preparations are well absorbed except when manufactured such that they do not disintegrate during oral ingestion. Absorption of calcium supplements is most efficient at individual doses of 500 mg or less and when taken between meals. Ingesting calcium supplements between meals supports calcium bioavailability, since food may contain certain compounds that reduce calcium absorption (e.g., oxalates). However, absorption of one form of calcium supplementation, calcium carbonate, is impaired in fasted individuals who have an absence of gastric acid. Absorption of calcium carbonate can be improved in these individuals when it is taken with certain food. The potential for calcium supplementation to interfere with iron absorption is an important consideration when it is ingested with meals. Alternatively, calcium supplementation in the form of calcium citrate does not require gastric acid for optimal absorption and thus could be considered in older individuals with reduced gastric acid production. In individuals with adequate gastric acid production, it is preferable to ingest calcium supplements between meals.

Maintenance of optimal bone health depends on an adequate supply of calcium and other essential nutrients. Current dietary intake data indicate that calcium intake is below recommended levels in most individuals. To attain the optimal calcium levels proposed, a change in dietary habits, including increased frequency of consumption of dairy products and/or calcium-rich vegetable sources, is needed. This approach of recommending the consumption of calcium-rich foods is consistent with current dietary guidelines (the U.S. Department of Agriculture (USDA) Food Guide Pyramid), which includes 2-3 servings per day of dairy products and 3-5 servings of vegetables. Recommendations for supplements should be made in the context of the total diet since recommendations are for calcium from all sources. The task for individuals to meet calcium requirements on a continuing daily basis is a formidable challenge.

## 5. What Public Health Strategies Are Available and Needed To Implement Optimal Calcium Intake Recommendations?

Optimizing the calcium intake of Americans is of critical importance. Recent improvements in calcium intake have been reported for most age groups (phase 1 of the Third National Health and Nutrition Examination Survey, 1988-1991--NHANES III). However, contemporary 6- to 11-year-old children showed a decrease in calcium intake, as compared with those a decade earlier (NHANES II, 1976-1980). NHANES III also documents that a large percentage of Americans still fail to meet currently recommended guidelines for calcium intake. The impact of suboptimal calcium intake on the health of Americans and the health care cost to the American public is a vital concern. It is thus appropriate that increasing calcium intake is a national health promotion and disease prevention objective in the Healthy People 2000 agenda (Department of Health and Human Services Publication Number 91.50212). Public health strategies to promote optimal calcium intake should have a broad outreach and should involve educators, health professionals, and the private and public sectors.

### Public Education

A public education program is needed to do the following:

- Disseminate consensus recommendations to the public.
- Convene meetings of public leaders and representatives of national groups to disseminate information on optimal calcium intake for the general population and high-risk groups and to develop action plans for public education.
- Develop health education materials and programs to address the diverse linguistic and cultural needs of the multiethnic American population.
- Work with existing national organizations and the mass media to distribute information, decrease consumer confusion, and encourage consumers, including children, adolescent girls, postmenopausal women, and older Americans, to adopt health-promoting changes in their daily calcium intake.

### Health Professionals

Primary care physicians, dentists, and other health professionals should play a strong role in educating their patients about bone health and calcium intake. An educational program to support this work of health professionals would:

- Disseminate consensus recommendations to health professionals.
- Develop and distribute educational materials, by serving as a clearinghouse for information on calcium-related research, and developing curricula for health professional training programs.
- Distribute educational materials through health professional organizations at their national and regional meetings.
- Initiate sessions at national meetings of health professionals focusing on promoting optimal calcium intake or initiating national meetings focusing specifically on calcium-related research.

### Private Sector

The private sector can play an active part in promoting optimal calcium intake.

- Manufacturers and producers of food products should continue to develop and market a wide variety of calcium-rich foods to meet the needs and tastes of our multiethnic population.
- Restaurants, grocery stores, and other food outlets should increase the accessibility and visibility of calcium-rich products for the consumer.
- Biotechnology research groups should develop accessible cost-effective technologies to screen for populations who are at high risk of fracture and who would be candidates for increased calcium intake.

### Public Sector

The Federal Government should take the following actions:

- The Government should ensure that guidelines for calcium intake across all agencies, departments, and institutions are consistent and that these guidelines reflect the current state of scientific knowledge.
- The National Center for Health Statistics and the USDA should widely disseminate their data on nutrient intakes and food consumption patterns, with respect to calcium, as well as their information on relevant trends in these nutrient intakes and food consumption patterns. To maximize educational, programmatic, and policy efforts, these data should be specific to age, gender, ethnic group, region, and socioeconomic status where possible.
- Existing Federal food and food subsidy programs and federally regulated facilities for infants, children, low-income populations, and the elderly in the Department of Health and Human Services, the Veteran Administration, the Department of Defense and other agencies should ensure achievement of optimal calcium intake for program recipients.
- The USDA should direct school food services to promote calcium intake by serving calcium-rich foods and to urge that calcium be included in all nutrition education efforts within public schools.
- Government cafeterias should serve as models to promote optimal calcium intake by serving calcium-rich foods, labeling calcium content in single servings of those foods, and distributing brochures about the relationship between dietary calcium needs and good health to their customers.
- Address, within health care reform, the need for financial coverage of calcium supplements for those who cannot reach optimal calcium intake through foods alone and financial support for screening of target populations to identify individuals who are at high risk of fracture and who would be likely to benefit from increased calcium intake.

## 6. What Are the Recommendations for Future Research on Calcium Intake?

- Prospective longitudinal studies to investigate long-term effects of calcium intake on regional (e.g., spine, hip, forearm) changes in bone mass and on fracture incidence in postmenopausal women and in older men.
- Prospective longitudinal studies of adolescent girls and boys to investigate the long-term effects of different levels of calcium intake on the achievement of peak bone mass.
- Studies to determine optimal calcium intake in the decade before the menopause and the potential role of declining estrogen levels during this time.
- Evaluation of the long-term effects of calcium intake on bone remodeling.
- Investigation of interactions between calcium supplementation and the absorption of other nutrients.
- Evaluation of dose-response relationships between calcium intake and estrogen replacement therapy.
- Determination of optimal calcium requirements in different ethnic populations.
- Evaluation of the effect of long-term calcium supplementation on the development or prevention of kidney stones.
- Studies on the effect of dietary calcium on bone mass and fracture incidence.
- Evaluation of the role of vitamin D metabolites in optimizing calcium balance.
- Development of a cost-effective means by which calcium-deficient individuals can be identified at all ages.
- Development of effective health-promoting programs to change population behavior with respect to calcium intakes that are tailored to specific age, sex, ethnic, socioeconomic status, and regional needs.
- Improved methods to achieve and maintain optimal dietary intake of calcium by both nutritional and supplemental means.

## Conclusions

- A large percentage of Americans fail to meet currently recommended guidelines for optimal calcium intake.
- On the basis of the most current information available, optimal calcium intake is estimated to be 400 mg/day (birth-6 months) to 600 mg/day (6-12 months) in infants, 800 mg/day in young children (1-5 years) and 800-1,200 mg/day for older children (6-10 years), 1,200-1,500 mg/day for adolescents and young adults (11-24 years), 1,000 mg/day for women between 25 and 50 years, 1,200 mg for pregnant or lactating women, and 1,000 mg/day for postmenopausal women on estrogen replacement therapy and 1,500 mg/day for postmenopausal women not on estrogen therapy. Recommended daily intake for men is 1,000 mg/day (25-65 years). For all women and men over 65, daily intake is recommended to be 1,500 mg/day, although further research is needed in this age group. These guidelines are based upon calcium from the diet plus any calcium taken in supplemental form.
- Adequate vitamin D is essential for optimal calcium absorption. Dietary constituents, hormones, drugs, age, and genetic factors influence the amount of calcium required for optimal skeletal health.
- Calcium intake, up to a total intake of 2,000 mg/day, appears to be safe in most individuals.
- The preferred source of calcium is through calcium-rich foods such as dairy products. Calcium-fortified foods and calcium supplements are other means by which optimal calcium intake can be reached in those who cannot meet this need by ingesting conventional foods.
- A unified public health strategy is needed to ensure optimal calcium intake in the American population.

## Consensus Development Panel

- John P. Bilezikian, M.D.
- Panel and Conference Chairperson
- Professor of Medicine and of Pharmacology
- Chief
- Division of Endocrinology
- Department of Medicine
- Columbia University College of Physicians and Surgeons
- New York, New York

- Lynn Bailey, Ph.D.
- Professor
- Department of Food Science and Human Nutrition
- University of Florida
- Gainesville, Florida

- Patricia J. Elmer, Ph.D., R.D.
- Associate Professor
- Division of Epidemiology
- School of Public Health
- University of Minnesota
- Minneapolis, Minnesota

- Murray J. Favus, M.D.
- Professor of Medicine
- Department of Medicine
- Director
- General Clinical Research Center
- Pritzker School of Medicine
- University of Chicago
- Chicago, Illinois

- Vay Liang W. Go, M.D.
- Professor of Medicine
- Division of Clinical Nutrition
- Department of Medicine
- Clinical Nutrition Research Unit
- UCLA School of Medicine
- Los Angeles, California

- Steven R. Goldring, M.D.
- Associate Professor of Medicine
- Harvard Medical School
- Chief of Rheumatology
- New England Deaconess Hospital
- Clinical Associate
- Massachusetts General Hospital
- Boston, Massachusetts

- Linda Hughey Holt, M.D.
- President
- Women's Medical Group
- Department of Obstetrics/Gynecology
- Evanston Hospital
- Skokie, Illinois

- Karl L. Insogna, M.D.
- Associate Professor of Medicine
- Director
- Yale Bone Center
- Division of Endocrinology
- Department of Internal Medicine
- Yale School of Medicine
- New Haven, Connecticut

- Barbara Krimgold
- Director
- Women's Health Project
- Women's Research and Education Institute
- Washington, DC

- Lawrence E. Mallette, M.D., Ph.D.
- Associate Professor of Medicine
- Department of Medicine/Endocrinology and Metabolism
- Baylor College of Medicine
- Houston, Texas

- Jay R. Shapiro, M.D.
- Professor
- Division of Geriatric Medicine and Gerontology
- Department of Medicine
- Johns Hopkins University School of Medicine
- Program Director
- General Clinical Research Center
- Johns Hopkins Bayview Medical Center
- Baltimore, Maryland

- Sachiko T. St. Jeor, Ph.D., R.D.
- Professor and Director
- Nutrition Education and Research Program
- University of Nevada School of Medicine
- Reno, Nevada

- Paula H. Stern, Ph.D.
- Professor
- Department of Molecular Pharmacology and Biological Chemistry
- Northwestern University Medical School
- Chicago, Illinois

- Barbara C. Tilley, Ph.D.
- Division of Biostatistics, Research Epidemiology, and Medical
- Informatics
- Henry Ford Health Sciences Center
- Detroit, Michigan

- Monica E. Yamamoto, Dr.P.H., M.P.H., M.S.F.N., M.S.Hyg., R.D.
- Nutrition Epidemiologist
- Department of Epidemiology
- Graduate School of Public Health
- University of Pittsburgh
- Pittsburgh, Pennsylvania

## Speakers

- Steven A. Abrams, M.D.
- "Attaining Peak Bone Mass-Infants"
- Assistant Professor
- Department of Pediatrics
- Children's Nutrition Research Center
- Baylor College of Medicine
- Houston, Texas

- Alberto Ascherio, M.D.
- "Epidemiological Studies on Calcium and Blood Pressure"
- Assistant Professor of Epidemiology and Nutrition
- Department of Nutrition
- Harvard School of Public Health
- Boston, Massachusetts

- John A. Baron, M.D.
- "Calcium Intake and Colorectal Cancer Risk"
- "Constipation and Possible Calcium Toxicity"
- Professor of Medicine and of Community and Family Medicine
- Dartmouth Medical School
- Hanover, New Hampshire

- Norman H. Bell, M.D.
- "Ethnicity and Calcium Metabolism"
- Professor of Medicine and Pharmacology
- Medical University of South Carolina
- Staff Physician
- Veterans Administration Medical Center
- Charleston, South Carolina

- Elizabeth A. Chrischilles, Ph.D.
- "Public Health Implications of Interventions To Promote Calcium Intake: Cost-Benefit Considerations"
- Associate Professor of Epidemiology
- Department of Preventive Medicine and Environmental Health
- College of Medicine
- University of Iowa
- Iowa City, Iowa

- Bess Dawson-Hughes, M.D.
- "Role of Calcium in Restraining Bone Loss in Postmenopausal Women"
- "Calcium Supplements"
- Associate Professor of Medicine
- Chief
- Calcium and Bone Metabolism Laboratory
- U.S. Department of Agriculture
- Human Nutrition Research Center on Aging at Tufts University
- Boston, Massachusetts

- Robert P. Heaney, M.D.
- "Cofactors Influencing the Calcium Requirement-Other Nutrients"
- John A. Creighton University Professor
- Creighton University
- Omaha, Nebraska

- Michael F. Holick, Ph.D., M.D.
- "Importance of an Adequate Source of Vitamin D for Calcium Metabolism"
- Professor of Medicine, Dermatology, and Physiology
- Chief
- Endocrinology, Diabetes, and Metabolism Section
- Director
- General Clinical Research Center
- Department of Medicine
- Boston University School of Medicine
- Boston, Massachusetts

- C. Conrad Johnston, Jr., M.D.
- "Life-Cycle Changes in Bone Mass"
- "Genetics"
- Professor of Medicine
- Chief
- Division of Endocrinology and Metabolism
- Department of Medicine
- Indiana University School of Medicine
- Indianapolis, Indiana

- Michael Kleerekoper, M.D., F.A.C.P.
- "Nutritional Requirements for Calcium in Secondary Osteoporosis"
- Professor of Medicine
- Director of Bone and Mineral Metabolism and Gerontology Research
- Division of Endocrinology
- Department of Internal Medicine
- Wayne State University School of Medicine
- Detroit, Michigan

- Jacob Lemann, Jr., M.D.
- "Kidney Stones and Hypercalciuria"
- Professor of Medicine
- Chief
- Division of Nephrology
- Department of Medicine
- Medical College of Wisconsin
- Milwaukee, Wisconsin

- Richard J. Levine, M.D.
- "Calcium Intake and Preeclampsia"
- Expert
- Epidemiology Branch
- Division of Epidemiology, Statistics, and Prevention Research
- National Institute of Child Health and Human Development
- National Institutes of Health
- Bethesda, Maryland

- Robert Lindsay, M.B.Ch.B., Ph.D., F.R.C.P.
- "Estrogens, Calcium, and Bone"
- Professor of Clinical Medicine
- Columbia University College of Physicians and Surgeons
- Chief
- Internal Medicine
- Helen Hayes Hospital
- West Haverstraw, New York

- Anne C. Looker, Ph.D.
- "Calcium Intake in the United States"
- "Current Dietary Behavior"
- Chief
- Nutrition Statistics Branch
- Division of Health Examination Statistics
- National Center for Health Statistics
- Hyattsville, Maryland

- Betsy C. Love, R.N., M.N.
- "Public Education"
- Associate Director
- Providence Osteoporosis Center
- Providence Medical Center
- Portland, Oregon

- Robert Marcus, M.D.
- "What Is the Interaction Between Calcium and Exercise?"
- Professor of Medicine and Endocrinology
- Stanford University School of Medicine
- Veterans Administration Medical Center
- Palo Alto, California

- Velimir Matkovic, M.D., Ph.D.
- "Attaining Peak Bone Mass-Adolescents"
- Associate Professor
- Departments of Physical Medicine and Rehabilitation, and of Medicine and Nutrition
- Director
- Bone and Mineral Metabolism Laboratory
- Davis Medical Research Center
- Ohio State University
- Columbus, Ohio

- L. Joseph Melton III, M.D., M.P.H.
- "Epidemiological Insights"
- Chair
- Department of Health Sciences Research
- Section of Clinical Epidemiology
- Mayo Clinic and Foundation
- Rochester, Minnesota

- Pierre J. Meunier, M.D.
- "Optimal Calcium Intake for Preventing Bone Loss and Fractures in the Elderly"
- Professor of Medicine
- Head of the Department of Rheumatology and Bone Diseases
- Hôpital Edouard Herriot
- Lyon, France

- Juan M. Navia, Ph.D.
- "Dental Manifestations of Inadequate Calcium"
- Professor of Public Health and Comparative Medicine (Retired)
- Department of Comparative Medicine
- University of Alabama at Birmingham
- Birmingham, Alabama

- Dorothy A. Nelson, Ph.D.
- "Evolutionary Aspects of Calcium Consumption"
- Associate Professor of Medicine
- Division of Endocrinology
- Department of Medicine
- Wayne State University School of Medicine
- Detroit, Michigan

- Eric S. Orwoll, M.D.
- "Restraining Bone Loss in Men"
- Chief
- Endocrinology and Metabolism Section
- Director
- Bone and Mineral Research Unit
- Medical Service
- Portland Veterans Administration Medical Center
- Associate Professor of Medicine
- Oregon Health Sciences University
- Portland, Oregon

- William A. Peck, M.D.
- "Overview: Calcium and Disease Prevention"
- Executive Vice Chancellor for Medical Affairs and Dean
- Professor of Medicine
- Washington University School of Medicine
- St. Louis, Missouri

- Robert R. Recker, M.D.
- "Attaining Peak Bone Mass-Young Adults"
- Professor of Medicine
- Section of Endocrinology and Metabolism
- Department of Medicine
- Center for Hard Tissue Research
- Creighton University School of Medicine
- Omaha, Nebraska

- Lawrence M. Resnick, M.D.
- "Hypertension: Clinical Studies"
- Professor of Medicine
- Division of Endocrinology
- Department of Internal Medicine
- Wayne State University School of Medicine
- Detroit, Michigan

- B. Lawrence Riggs, M.D.
- "Calcium Homeostasis and Skeletal Health"
- Professor of Medicine
- Divisions of Endocrinology and Metabolism
- Mayo Clinic and Foundation
- Rochester, Minnesota

- Frederick R. Singer, M.D.
- "Other Bone Diseases"
- Director
- Skeletal Biology Laboratory
- John Wayne Cancer Institute
- Santa Monica, California

- Charles W. Slemenda, Dr.P.H.
- "The Role of Calcium Nutrition in Skeletal Growth in Children"
- Associate Professor of Medicine
- Division of Biostatistics
- Department of Medicine
- Riley Hospital for Children
- Indiana University Medical Center
- Indianapolis, Indiana

- MaryFran R. Sowers, Ph.D.
- "Changes in Maternal Bone With Pregnancy and Lactation: A Role for Dietary Calcium Intake"
- Associate Professor of Epidemiology
- Department of Epidemiology
- School of Public Health
- University of Michigan
- Ann Arbor, Michigan

- Connie M. Weaver, Ph.D.
- "Bioavailability of Calcium"
- Department Head and Professor
- Foods and Nutrition
- Purdue University
- West Lafayette, Indiana

## Discussants

- Sanford A. Miller, Ph.D.
- Dean
- Graduate School of Biomedical Sciences
- University of Texas Health Science Center
- San Antonio, Texas

- Walter C. Willett, M.D., Dr.P.H.
- Chair
- Department of Nutrition
- Harvard School of Public Health
- Department of Medicine
- Channing Laboratory
- Harvard Medical School
- Boston, Massachusetts

## Planning Committee

- Lawrence E. Shulman, M.D., Ph.D.
- Planning Committee Chairperson
- Director
- National Institute of Arthritis and Musculoskeletal and Skin Diseases
- National Institutes of Health
- Bethesda, Maryland

- Elia Ben-Ari, Ph.D.
- Science Writer
- Office of Scientific and Health Communications
- National Institute of Arthritis and Musculoskeletal and Skin Diseases
- National Institutes of Health
- Bethesda, Maryland

- John P. Bilezikian, M.D.
- Panel and Conference Chairperson
- Professor of Medicine and of Pharmacology
- Chief
- Division of Endocrinology
- Department of Medicine
- Columbia University College of Physicians and Surgeons
- New York, New York

- Elsa Bray
- Program Analyst
- Office of Medical Applications of Research
- National Institutes of Health
- Bethesda, Maryland

- Mona S. Calvo, Ph.D.
- Clinical Research and Review Staff
- Office of Special Nutritionals
- Center for Food Safety and Applied Nutrition
- Food and Drug Administration
- Washington, DC

- Bess Dawson-Hughes, M.D.
- Associate Professor of Medicine
- Chief
- Calcium and Bone Metabolism Laboratory
- U.S. Department of Agriculture
- Human Nutrition Research Center on Aging at Tufts University
- Boston, Massachusetts

- Nancy D. Ernst
- Nutrition Coordinator
- Division of Epidemiology and Clinical Applications
- National Heart, Lung, and Blood Institute
- National Institutes of Health
- Bethesda, Maryland

- John H. Ferguson, M.D.
- Director
- Office of Medical Applications of Research
- National Institutes of Health
- Bethesda, Maryland

- Gilman D. Grave, M.D.
- Chief
- Endocrinology, Nutrition, and Growth Branch
- Center for Research for Mothers and Children
- National Institute of Child Health and Human Development
- National Institutes of Health
- Bethesda, Maryland

- John G. Haddad, M.D.
- Professor
- Division of Endocrinology
- Department of Medicine
- University of Pennsylvania School of Medicine
- Philadelphia, Pennsylvania

- William H. Hall
- Director of Communications
- Office of Medical Applications of Research
- National Institutes of Health
- Bethesda, Maryland

- Stephen P. Heyse, M.D., M.P.H.
- Director
- Office of Prevention, Epidemiology, and Clinical Applications
- National Institute of Arthritis and Musculoskeletal and Skin Diseases
- National Institutes of Health
- Bethesda, Maryland

- Van S. Hubbard, M.D., Ph.D.
- Chief
- Nutritional Sciences Branch
- Acting Director
- Division of Nutrition Research Coordination
- National Institute of Diabetes and Digestive and Kidney Diseases
- National Institutes of Health
- Bethesda, Maryland

- C. Conrad Johnston, Jr., M.D.
- Professor of Medicine
- Chief
- Division of Endocrinology and Metabolism
- Department of Medicine
- Indiana University School of Medicine
- Indianapolis, Indiana

- Anne C. Looker, Ph.D.
- Chief
- Nutrition Statistics Branch
- Division of Health Examination Statistics
- National Center for Health Statistics
- Hyattsville, Maryland

- Joan A. McGowan, Ph.D.
- Director
- Bone Biology and Bone Diseases Branch
- National Institute of Arthritis and Musculoskeletal and Skin Diseases
- National Institutes of Health
- Bethesda, Maryland

- William A. Peck, M.D.
- Exec. Vice Chancellor for Medical Affairs and Dean
- Professor of Medicine
- Washington University School of Medicine
- St. Louis, Missouri

- Marjorie Perloff, M.D.
- Program Director
- Chemoprevention Branch
- Division of Cancer Prevention and Control
- National Cancer Institute
- National Institutes of Health
- Rockville, Maryland

- Ellyn J. Pollack
- Information Officer
- Office of Research on Women's Health
- Office of the Director
- National Institutes of Health
- Bethesda, Maryland

- Maryann Reford, D.D.S., M.P.H.
- Public Health Specialist
- Epidemiology and Oral Disease Prevention Program
- National Institute of Dental Research
- National Institutes of Health
- Bethesda, Maryland

- Pamela E. Stark-Reed, Ph.D.
- Director
- Office of Nutrition
- National Institute on Aging
- National Institutes of Health
- Bethesda, Maryland

- Connie M. Weaver, Ph.D.
- Department Head and Professor
- Department of Foods and Nutrition
- Purdue University
- West Lafayette, Indiana

## Conference Sponsors

- Office of Medical Applications of Research, NIH
- John H. Ferguson, M.D.
- Director

- National Institute of Arthritis and Musculoskeletal and Skin Diseases
- Lawrence E. Shulman, M.D., Ph.D.
- Director