# Combined Liver-Kidney Transplantation

## Report

In 1984, Margreiter et al(1). performed the first combined liver-kidney transplantation (CLKT). This procedure has recently been considered a therapeutic option for those patients suffering from concomitant liver and kidney disease.(2,3). Multiple organ transplantation is performed in order to improve long-term allograft function by correcting the coexisting dysfunction of other organ systems. Renal and hepatic failure may result from the same disease process (e.g., polycystic disease), one disease may be a result of the other (e.g., postviral hepatic cirrhosis in a dialysis patient) or they may be unrelated but concomitant.(2).

Weir et al(4). reported that hepatic disease was the leading cause of late mortality among their renal transplant recipients with grafts functioning for more than 5 years. Moreover, a number of potential liver transplant candidates may have preexisting renal dysfunction. Where correction of such renal dysfunction is not expected, the post-liver transplant management of the patient with chronic kidney failure is problematic. Impaired renal function has been considered by some to be a contraindication for liver transplantation. (2,5). Normal kidney function would allow the use of therapeutic levels of cyclosporine to ensure adequate immunosuppression, without fear of further damage to compromised kidneys. Therefore, when irreversible and severe chronic renal disease is documented before hepatic transplantation, CLKT has been considered with the intent of also providing normal kidney function.(2).

Liver transplantation has been performed in cases of inborn errors of liver metabolism resulting from genetically determined enzyme deficiencies where destruction of the host liver is certain (e.g., [alpha]-1-antitrypsin deficiency, tyrosinemia). (6). CKLT have been reported for two cases of hepatorenal tyrosinemia (a heterogeneous hereditary disorder) with severe renal involvement.(7).

Primary hyperoxaluria type 1 (PH1) is an inborn error of liver metabolism resulting in renal failure. There is no satisfactory treatment for this condition; typically, patients develop renal insufficiency early in life and succumb to uremia before age 20.(8). Scheinman(9). estimates that 10 to 15 new patients per year in the United States will be recognized with end-stage renal failure due to PH1. CLKT for the treatment of PH1 was reported in 1985 and again in 1987 by Watts et al(10,11). and has been proposed as a way of replacing the destroyed kidney, correcting the enzyme deficiency, and normalising oxalate production and excretion. Rosenberg(8). and Hillman(12). recommend clinical studies with long-term followup to evaluate this potentially promising therapy. Presently, there are no published reports of United States experience with CLKT for PH1. However, there is European experience;(13). a 1-year graft survival rate of 77 percent for both organs was achieved in 13 of 17 patients. Currently, the role of CLKT in patients with oxalosis is not clearly defined.

There have been a total 273 CLKTs performed in the United States since 1987, with followup data available on 268 patients. More than 80 percent of the procedures have been performed since 1990. In the first 6 months of 1993, there were 19 CLKT procedures reported. The number of separate liver and kidney transplants continues to rise: since 1987, there have been almost 17,000 livers transplanted, increasing from a little more than 1,000 in 1987 to over 3,000 in 199. Kidney transplants averaged about 8,700 in 1988 and 1989 and have increased to almost 10,000 in 1992, according to a Federal Report on organ transplantation(14). and the United Network for Organ Sharing (UNOS) (written communication, November 2, 1994).

A paucity of published data exists on patient outcomes after CLKT Experience for CLKT is reported in only a few studies with small series of patients (Table 1). Most patients receive organs from the same donor, with the liver transplanted first. Patients selected had various combinations of liver and kidney disease and were monitored for periods ranging from 1 month to 7 years posttransplant. Clinical outcomes for specific disease combinations were either not provided or represented the experience of only a few patients.

Table 1. Outcome data for studies of CLKT

Reference no. | Number of patients | Duration of followup | Patient survival (percent) | Liver graft function (percent) | Kidney graft function (percent)
2 | 38 | 1-7 yr | 68 | 64 | 60
3 | 8 | 17+/-12 mo | 88 | 88 | 88
13 | 22 | 1-41 mo | 77 | 77 | 64
15 | 4 | 5-35 mo | 100 | 100 | 100
5 | 7 | 6 wk-32 mo | 86 | 71 | 86
UNOS | 268 | NA | 72.5 [a] | NA | NA

[a] Survival rates were estimated using the Kaplan-Meier method. (16).

Abbreviations: ABMT = autologous bone marrow transplantation; BMT = bone marrow transplantation.

Seventy-nine patients have been reported in the medical literature as recipients of CLKT. Thirty-one (39 percent) of these had end-stage liver disease due to hepatitis and/or postnecrotic cirrhosis, and 18 (23 percent) with chronic kidney failure receiving a CLKT, presented with glomerulonephritis or chronic graft rejection. In 10 percent of the patients, the cause of renal failure was unknown. The 25 patients (32 percent) receiving a CLKT for primary hyperoxaluria (oxalosis) constituted the largest single category.

Additional patient outcome data regarding liver-kidney recipients are available from the United States UNOS data base. UNOS operates the national Scientific Registry for Organ. Transplantation, which collects data from member transplant programs; transplant recipients are monitored from the time of transplant until 2 years after the failure of the graft or until the death of the recipient. The estimated percentage of survivors to 1 year is approximately 73 percent, with a 95 percent confidence interval of 66.8 to 78.2 percent, for 268 of thes transplant patients for whom followup data were available (Table 1) (UNOS written communication, November 2, 1994. Forty-five of the 79 patients in the medical literature are from U.S. studies and are probably included as part of thee UNOS registry. Data regarding patient outcomes for specific combinations of liver and kidney disease are limited.

The relationship between tissue typing and the outcome of transplant procedures remains equivocal and appears to be organ specific.(17,18). In CLKT studies, ABO blood group typing was typically performed to provide identical or compatible donors. Human leukocyte antigen (HLA) tissue typing indicated generally poor matches. The cytotoxic cross-matches reported in most studies were usually negative. However, ABO compatibility and organ size were the only criteria used for selecting donors. Improvements in immunosuppressive therapy appear to have diminished greatly the effects of HLA mismatching on graft survival.(19). Under current UNOS policy, only kidney allocations address the degree of antigen mismatches. Current UNOS policy does not directly address CLKT. Data are insufficient to determine the effect of HLA matching, particularly at the DR locus, on graft survival for CLKT.

A review of the transplantation history of patients receiving CLKT revealed that some patients had received kidney or liver transplants before the CLKT, and that some required subsequent retransplantation of the liver and/or kidney (Table 2). For example, in the largest series, 34 percent of the patients had a previous transplant, and for all five studies reported in Table 2, approximately 39 percent of the CLKT patients had a previous transplant. Twenty-seven percent of the 268 patients in the UNOS CLKT registry had a prior transplant. In contrast, approximately 15 percent of recipients of isolated kidney (cadaveric) or liver transplants had previous transplants.(14). Patients receiving CLKT (UNOS) were almost twice as likely to have had a previous transplant than were single-organ recipients. In the largest single study,(2). 102 organs were expended by 38 patients. Regarding retransplantation, there is insufficient information to determine any trends in the CLKT population.

Table 2. Transplant history of patients receiving CLKT's

| | Number of previous transplants | | | Number of retransplantations | | | Number of organs
Reference | Number of patients | Patients (percent) | Liver | Kidney | Patients (percent) | Liver | Kidney | Total organs | Liver | Kidney
Saidman(2). | - 38 | - 13; - (34) | - 8 | - 9 | - 9; - (24) | 6 | 3 | 102 | 52 | 50
Gil-Vernet(3). | - 8 | - 4; - (50) | 0 | 4 | 0 | 0 | 0 | 20 | 8 | 12
Watts(13). | - 22 | - 12; - (55) | 0 | 17 | 0 [a] | 0 | 0 | 61 | 22 | 39
Vogel(15). | - 4 | - 2; - (50) | 0 | 2 | 0 | 0 | 0 | 10 | 4 | 6
Gonwa(5). | - 7 | - 0; - (0) | - 0 | - 0 | - 2; - (25) | 2 | 1 | 17 | 9 | 8
Total | - 79 | - 31; - (39) | - 8 | - 32 | - 11; - (14) | 8 | 4 | 210 | 95 | 115
UNOS [b] | - 268 | - 73; - (27) | 44 | 49 | NA | NA | NA | NA | NA | NA

[a] Three patients on dialysis.

[b] Written communications, November 2, 1994.

Abbreviations: ABMT = autologous bone marrow transplantation; BMT = bone marrow transplantation.

At present, it is not possible to determine confidently the most appropriate role for CLKT, because case series total 79 patients, and overall, only 268 CLKT appear in the UNOS registry. However, even this limited information may permit several preliminary observations. The data comprise relatively short-term followup in a small number of presumably carefully selected patients; moreover, the wide spectrum of kidney and liver diseases in the recipients makes it impractical to frame specific and rational patient selection criteria aside from simultaneously observed (or expected, in the case of certain metabolic diseases) kidney and liver failure. It is unclear whether the more widespread use of the technique with longer followup will continue to provide similar results.

Notwithstanding, the information reported by UNOS (Table 3) indicates that the 1-year survival rate after CLKT in those patients not previously transplanted (79.7 percent) is comparable to that for primary liver transplant alone (81.7 percent). Because liver function is very likely to be the primary determinant of patient survival, it appears that simultaneous kidney transplant does not adversely affect the transplanted liver. However, the results differ markedly for those patients who received a transplant prior to the CLKT (27 percent of the total). In the letter group, a 1-year survival rate of 56.4 percent was reported for patients with any prior transplant, and only 40.9 percent for those having had prior liver transplant. The 1-year survival rate for patients receiving a liver transplant (first transplant) was reported as 81.7 percent, and only 57.8 percent for those patients having had a prior liver transplant.

Table 3. Survival of patients and grafts [a]

| Number and survival rates (percent)
Category | All transplants [b] | No prior transplant | Prior transplant
Cadaveric kidney | 38,599 | 32,558 | 5,908(15)
1-yr graft survival | 80.3 | 81.3 | 74.8
Liver | 12,869 | 11,188 | 1,681(13)
1-yr patient survival | 78.6 | 81.7 | 57.8
1-yr graft survival | 68.0 | 70.8 | 49.8
CLKT | - 268 [c] | - 168 | - 49 (18) kidney; - 44 (16) liver
1-yr patient survival | - 72.5 | - 79.7 | - 60.3 kidney; - 40.9 liver

[a] Adapted from UNOS communication, November 2, 1994.

[b] UNOS transplant data from October 1, 1987, to December 31, 1992.

[c] UNOS transplant data from October 1, 1987, to March 31, 1994.

It would appear that, at least for the first year after transplant, CLKT performed as the initial procedure for patients with both liver and kidney failure is of equal effectiveness regarding survival as is isolated liver transplantation in patients with liver failure alone. CLKT after prior liver transplant appears to be associated with a significant decrement in survival, not unlike the decrement in the survival rate of liver transplant patients who had received a prior transplant. This is not a trivial issue, because donor organs represent a scarce resource. Retransplantation is therefore problematic, because in 1993, 500 (8.0 percent) of those awaiting liver transplant died. This observation may require careful evaluation by those charged with the establishment of organ distribution policies.

The National Institutes of Health finds that CLKT is a beneficial procedure and acknowledges that patients who have had a prior liver transplant are less likely to benefit from a CLKT.

## References

1 Margreiter R, Reinhard K, Christoph H, et al. Kramar R, Huber C, et. al. Combined liver and kidney transplantation. Lancet. 1984;;1:1077-1078. [pmid: 6144007].
2 Saidman SL, Duquesnoy RJ, Demetris AJ, et al. Simultaneous liver-kidney transplantation: The influence of performed lymphocytotoxic antibodies. Transplant Immunol, in press.
3 Gil-Vernets, Prieto JM, Grino O. Combined liver-kidney transplantation. Transplant Proc. 1992;;24:128-129. [pmid: 1539207].
4 Weir MR, Kirkman RL, Strom TB, et al. Liver disease in recipients of long-functioning renal allografts. Kidney Int. 1985;28:839-844. [pmid: 3910917].
5 Gonwa TA, Nery JR, Husberg BS, et al. Simultaneous liver and renal transplantation in man. Transplantation. 1988;46:690-693. [pmid: 3057691].
6 McDonald JC, Landreneau MD, Rohr MS, et al. Reversal by liver transplantation of the complications of primary hyperoxaluria as well as the metabolic defect. N Engl J Med. 1989;321:1100-1103. [pmid: 2797068].
7 Paradis K, Weber A, Seidman EG, et al. Liver transplantation for hereditary tyrosinemia: The Quebec experience. Am J Hum Genet. 1990;47:338-342. [pmid: 2378360]. [pmcid: 1683709].
8 Rosenberg LE. Inherited disorders of amino acid metabolism in Wilson JD, Braunwald E, Isselbacher KJ, et al (Eds): Harrison's Principles of Internal Medicine (12th ed), New York: McGraw-Hill, Inc, 1991 pp 1876 1877
9 Scheinman JI. Editorial review. Primary hyperoxaluria: Therapeutic strategies for the 90's. Kidney Int. 1991;40:389-399. [pmid: 1787639].
10 Watts RWE, Caline Calne RY, Williams R, et al. Primary hyperoxaluria (Type I): Attempted treatment by combined hepatic and renal transplantation. Q J Med. 1985;57:697-703. [pmid: 3909198].
11 Watts RWE, Rolles K, Morgan SH, et al. Successful treatment of primary hyperoxaluria type I by combined hepatic and renal transplantation. Lancet. 1987;2:474-475. [pmid: 2887776].
12 Hillman RE. Primary hyperoxalurias in Scriver CR, Beaudet AL, SLy WS, et al. (Eds): The Metabolic Basis of Inherited Disease (6th ed), New York: McGraw-Hill, Inc, 1989 pp 933 941
13 Watts RWE, Danpure CJ, DePaul L, et al. Combined liver-kidney and isolated liver transplantations for primary hyperoxaluria type I: The European experience. Nephrol Dial Transplant. 1991;6:502-511. [pmid: 1922912].
14 U.S. Department of Health and Human Services Annual Report of the U.S. Scientific Registry for Organ Transplantation and the Organ Procurement and transplantation Network, Washington, DC: U.S. Department of Health and Human Services, Public Health Service, Health Resources and Services Administration, Bureau of Health Resources Development, Division of Organ Transplant 1990
15 Vogel W, Steiner E, Kornberger R, et al. Preliminary results with combined hepatorenal allografting. Transplantation. 1988;45:491-493. [pmid: 3278443].
16 Kaplan EL, Meier P. Nonparametric estimation from incomplete observations. J Am Stat Assoc. 1958;53:457-481.
17 Roitt I. Transplantation in: Essential Immunology, Oxford: Blackwell Scientific Publications, 1991 pp 277 304
18 Sachs DH. The major histocompatibility complex in Paul WE (Ed): Fundamental Immunology, New York: Raven Press, 1984 pp 303 346
19 Perkins HA. Transplantation immunology in Fudenberg HIH, Stites DP, Calwell JL, et al (Eds): Basic and Clinical Immunology, Los Altos, CA: LANGE Medical Publications, 1976, pp 160 169