# External and Implantable Infusion Pumps

## Introduction

The Office of Health Technology Assessment (OHTA) has previously published five technology assessments on infusion pumps: three on external infusion pumps (two on insulin and one on heparin), and two on implantable infusion pumps (chemotherapy of liver cancer and chronic heparin therapy).(1-5).

In this technology review, OHTA, which is part of the Agency for Health Care Policy and Research, Public Health Service, has combined several requests from the Health Care Financing Administration (HCFA) for technology assessments on drug-device delivery systems. Specifically, HCFA requested that OHTA evaluate the safety and effectiveness of: chemotherapeutic agents, used with an external infusion pump (EIP) or implantable infusion pump (IIP), access system, and temporary or permanent indwelling catheter; morphine for intractable malignant and nonmalignant pain, used with an EIP or IIP, access system, and temporary or permanent indwelling catheter; and intrathecal baclofen for chronic, intractable spasticity. Additionally, the appropriate settings and clinical situations for use of both EIP and IIP were to be identified.

This report is divided into two sections: classification and description of EIPs and IIPs; and review of the literature and discussion of the effectiveness of implantable infusion devices when used to administer chemotherapy for metastatic liver disease, morphine for chronic pain, or baclofen for chronic spasticity. It will not address the use of external or internal pumps to deliver heparin, insulin, or antibiotics, or for unlabeled (unapproved) drug uses. For preparation of this report, an extensive literature review was undertaken, encompassing all journals and textbooks available through on-line search capabilities (PaperChase). The following medical subject headings (i.e., MeSH terms) were used: cytotoxic agents, drug therapy, pain/nonmalignant, pain/chronic, antispasmodic drug therapy, infusion pumps/implantable.

The search was limited to human studies published in English from 1984-1992. It was expanded to include pertinent references cited in reviewed articles and texts, and was contracted to exclude case reports, uncontrolled studies, animal studies, and studies of unapproved drugs and devices. During the literature search, it became clear that "infusion pumps" is a subject heading used interchangeably to describe several different kinds of medical devices, including implantable or transcutaneous catheters connected to EIPs, access ports or reservoirs, and IIPs.

## Background

Infusion pumps are an important means of drug delivery in a wide range of clinical conditions, such as cancer therapy and chronic pain therapy. The functional requirements of infusion pumps include reliability, precision, safety, simplicity in handling and maintenance, light weight, biologic compatibility (for implantables), easy access, long-acting power source or batteries, and chemical compatibility with the drug to be infused. All of the benefits of these pumps necessarily require that the delivery system use a drug that is effective for the clinical condition in question.

The flow range and reservoir capacities of EIPs vary among manufacturers and extend from simple, manually-set, gravity-flow drip rate controllers and volumetric infusion pumps to sophisticated, programmable infusion delivery systems.(6). Miniaturization and microprocessor control have made IIPs comparable to EIPs in terms of performance characteristics. The IIPs have been developed primarily to promote patient independence from the hospital setting during chronic infusion therapy, particularly for pain control and chemotherapy Other devices, such as implantable drug pellets and capsules (for hormone delivery) and rate-specified pharmaceuticals (i.e., pilocarpine or intrauterine progesterone) are considered to be implantable drug delivery devices but are beyond the scope of this report.

Components for both EIPs and IIPs include the infusion pump and reservoir, bacteriostatic filters, fluid administration sets, and delivery catheters. No device standards exist for external or internal diameter size, and many EIP components are interchangeable among manufacturers. The IIPs are usually sold as a complete infusion system with all necessary components. Table 1 summarizes currently available EIPs and IIPs.

Table 1. External and implantable infusion pumps

Placement and type | | Power source | Flow rate
External | - Peristaltic; - Cassette; - Syringe; - Elastomeric | - Step motor with rollers, compression; - Motor-driven plungers; - Motor-driven lead screw; - Pressurized reservoir | - Variable, programmable; - Variable, programmable; - Variable; - Fixed
Implantable | - Vapor-pressure powered; - Pulsatile; - Peristaltic | - Compressed fluorocarbon; - External manual pressure; - Lithium-thionyl chloride battery | - Fixed; - Bolus; - Variable, programmable

## External infusion pumps

There are over 600 different models of EIPs, most of which have been approved for marketing by the Food and Drug Administration (FDA) through a prenotification application (510(k)).(7). These devices are labeled for general use and, if marketed before 1991, may not have undergone human clinical trials for safety and effectiveness. None of the infusion pumps are specifically labeled for home or nonhospital use, although this use is common.(8). Rather, the FDA classifies infusion pumps into functional categories: implantable, ambulatory, and patient-controlled analgesia pumps.

The majority of EIPs are used to administer antibiotics, particularly in the nonhospital setting. Other uses include administration of chemotherapy, analgesics and opioids, total parenteral nutrition formulas, insulin, lipids, vasopressors, blood products, and other drugs or biologics for which a controlled rate of delivery is desirable or necessary. The EIP requires a disposable administration set and an optional micropore filter, to be used with a variety of delivery catheters. The functional range of EIP infusion rates extends from high volume delivery (400 mL/h) for hydration therapy to very low flow rates (0.04 mL/h) that can be used for chemotherapeutic agents.

Recently, ECRI evaluated several noninsulin EIPs.(9). A variety of models allow continuous, intermittent, or bolus administration by means of a programmer controlled by a physician or pharmacist. Other, nonprogrammable pumps offer continuous, fixed-rate flows. System alarms are generally present to warn both patient and provider of occlusion, battery malfunction, empty reservoir, and air in the line. The proposed use (chemotherapy, rehydration, analgesia) will influence the choice of model or device, because of the specific performance requirements in those applications (flow rate, bolus dosing, external reservoirs).

External infusion pumps are available in four distinct designs: peristaltic, cassette, syringe, and elastomeric(7). (Table 1.). Linear peristaltic pumps are the most common ones used today. The fluid administration set is placed in a pump channel, where finger-like eccentric disks occlude the tubing successively, in a rippling, wave-like motion. The tubing is held against a stationary back plate and alternately compressed and released by the moving fingers, forcing fluid to flow. Rotary peristaltic pumps use a short length of tubing (usually silicone rubber) held taut around rollers that have been mounted on a rotor. As the rotor is turned at precise speeds by a motor drive, the rollers occlude the tubing and force the fluid into the patient at a prescribed rate.

Cassette pumps include either of two designs: motor-driven plungers or piston-actuated diaphragms. The motor-driven plunger has a syringe-like action in which the plunger moves in and out of a cylinder. The inward motion pumps the fluid out of the cassette toward the patient, while the outward motion draws fresh fluid from the solution container to refill the cassette. In the other type of cassette pump, a diaphragm is mounted near a moving piston that displaces a small volume of fluid toward the patient with each inward stroke and allows the diaphragm to refill with each outward stroke. Syringe infusion pumps expel fluid from a syringe by advancing either the plunger or the barrel of the syringe at a predetermined rate. In most of these syringe pumps, a motor drives a lead screw or gear mechanism. The speed of the motor controls the rate of delivery of solution. Elastometric infusion pumps have a pressurized balloon reservoir connected with kink-resistant tubing to a small distal flow restrictor that provides a single, fixed-flow rate. The approved labeling for these devices, in general, allows 15 tolerance in accuracy for flow rates, although flow-rates are usually within 5, even at low rates.(9).

In its evaluation of some currently marketed EIPs, ECRI tested the performance and safety of EIPs by measuring a range of flow rates and reservoir volumes for different applications.(9). It also tested flow accuracy under a variety of operating conditions that can be found in ambulatory use: high viscosity fluids, infusate temperature variations, low battery, extended use (beyond 72 hours), high back pressures and negative pressures, electromagnetic interference and electrostatic discharge, and ease of use (human factors). Further, it listed the performance characteristics of pumps tested, so that suitability for the four major infusion indications (chemotherapy, pain control, antibiotics, total parenteral nutrition) could be evaluated by a provider. It concluded that there were no major performance failures in those pumps evaluated for flow rates, reservoir capacity and programming features.

The drug delivery catheters used with infusion pumps are inserted percutaneously into a peripheral vein or subcutaneous space, tunneled over a guide wire into a central vein from a distal insertion site, or surgically implanted into an artery, or other compartment. When EIPs are used over an extended period of time, peripheral delivery catheters should be replaced every 48-72 hours to reduce the incidence of entry-site infection and phlebitis. More permanent catheters, such as the Hickman, and access ports are usually cannulated into central vessels and have an extended period of usefulness (weeks or months). External infusion pumps produce measurable, predictable, and controllable flow rates and have eliminated reliance on less accurate timing methods such as manual flow adjustment. They have made infusions possible against greater than venous pressures by active mechanical pumping. Some of the advantages of using EIPs are ease in establishing a controlled delivery rate, portability, reusability, and cost. They have battery backup power sources and can be mounted on carrier poles, or worn with a shoulder strap or backpack that permit a range of activities by the user.

Adverse effects associated with use of EIPs reflect complications similar to other infusion devices and delivery catheters. They include overinfusion, underinfusion, infection, phlebitis, emboli, and fluid extravasation. In a recent FDA report, malfunctions (battery, software, alarms, displays), and user error were found to be associated with adverse effects.(10). Many of the early designs were not user-friendly, were subject to performance degradation in the very locations for which they had been designed, and end users lacked proper training.

## Implantable Infusion Pumps

Implantable infusion pumps are distinguished from devices such as an implanted access port or pulsatile pump by the way the bulk flow of drug is generated, either by fluorocarbon propellant or direct electromechanical action powered by a battery.(11).

The unsuitability and inconvenience of existing routes of drug administration for provision of site-specific drug therapy, as well as the need for chronic intravenous and subcutaneous infusions, led to the development of implantable drug delivery systems. Programmable and nonprogrammable IIPs are capable of delivering therapeutic plasma levels of active drug to a target organ or compartment for prolonged periods of time. Programmable IIPs have variable delivery rates that are set and adjusted through radiofrequency control. Nonprogrammable pumps deliver predetermined, constant rates of infusate and are limited in their ability to provide bolus or modulated patterns of delivery.

Two IIPs are currently approved by FDA for marketing: a nonprogrammable vapor-pressure powered (flourocarbon propellant) pump, and a programmable peristaltic pump.(12). Other designs have been reported in the literature but are not approved for marketing at this time. The pumps are implanted in a subcutaneous pocket and connect to a dedicated catheter that has been placed in the appropriate compartment. Constant or variable-rate infusions are possible over long periods of time (several weeks to years) with minimal human intervention (refilling or reprogramming), while the capability for external control of rate and volume of primary and supplemental drug delivery is retained.(11). The pumps are labeled for specific drugs and routes of administration, e.g., intravenous fluorouracil (5-FU), intra-arterial floxuridine, epidural morphine sulfate, intrathecal morphine sulfate, and intrathecal baclofen.

Implantation of infusion pumps was first attempted in the early 1960s, particularly for insulin delivery. Today, the objectives of implantable drug-delivery systems include: provision of long-term access to various compartments of the nervous and vascular systems (epidural, subarachnoid, hepatic artery) to enable site-specific drug therapy; reduction in infections at the injection site that are associated with external access devices; and provision of drug delivery through a device or system that promotes patient mobility and independence (Table 2.). (13).

Table 2. Classification of implantable drug delivery system.(13)

Type of system | Description | Purpose
I | Percutaneous epidural or intrathecal (subarachnoid) catheter. | Used initially for obstetrics. Now used for postoperative pain and obstetrics. There are three oncology uses: acute temporary postoperative palliation, near-death palliation, and as a trial for more permanent system.
II | Percutaneous epidural or intrathecal catheter with subcutaneous tunneling (i.e., Broviac, Hickman). | Used for long-term delivery of opioids in patients with very short life expectancies (weeks). Can be attached to an external infusion pump and is flexible in terms of ease of administration, catheter care, etc.
III | Totally implanted epidural or intrathecal catheter with subcutaneous injection port (i.e., access port). | Used for chronic constant-rate infusions in patients with limited life expectancies (months to a few years) who have obtained good pain relief from trial doses of intraspinal opioids. Insertion and removal require surgical incision; injections more difficult because of subcutaneous location. Can be used with an external infusion pump.
IV | Totally implanted epidural or intrathecal catheter with implanted manually activated pump (i.e., pulsatile). | Used for bolus administration of patient-controlled drugs, such as opioids. Maximum patient-controlled flexibility.
V | Totally implanted epidural or intrathecal catheter with implanted infusion pump (i.e., vapor-pressure powered). | Used for chronic drug infusion of opioids, and chemotherapeutic agents. Suitable for patients with limited life expectancies who require continuous plasma levels, rather than bolus doses. Requires infrequent filling, and has capability for auxiliary bolus drug administration, such as local anesthetics. More expensive than types I-IV.
VI | Totally implanted epidural or intrathecal catheter with implanted programmable infusion pump (i.e., peristaltic). | Used for chronic drug infusions of opioids, chemotherapeutic agents, antispasmodics, with capabilities for customized delivery patterns and bolus administrations.

### Access ports

Although technically not infusion pumps, a description of implanted access ports and pulsatile pumps are included here because they have been used clinically to administer long-term drug therapy, have been reported in the literature as implantable infusion devices, and have been successfully used for long-term infusions of chemotherapeutic drugs, antibiotics, and opioids. Clinical studies that compare the effectiveness of access ports and IIPs are reviewed below.

Access ports are subcutaneously implanted, rigid reservoirs with injection ports. The reservoirs are connected internally to catheters terminating in a compartment (i.e., subarachnoid space or hepatic artery).(11). They are manufactured from relatively biocompatible materials such as titanium, stainless steel, polysulfone, or reinforced silicone, in a variety of sizes and volume capacities. To refill the access port with drug, a self-sealing, rubber septum over the reservoir is punctured transcutaneously with a Huumlberlike noncoring needle. The septum determines the useful lifetime to the access port, which is designed to accept multiple refills (some, up to a few thousand). The rate of drug delivery is controlled by passive diffusion, since drug concentration in the reservoir is greater than in the target compartment. There is no battery or other power source. Because the reservoir volume is small it needs to be filled manually at frequent intervals (hours or days). Subcutaneous reservoirs have been used as a permanent delivery system, as well as temporary reservoirs for patients undergoing evaluation for permanent epidural or intrathecal drug delivery systems.

Virtually any marketed drug can be delivered through a subcutaneous reservoir, even though a particular drug may not have undergone pharmacokinetic evaluation by this route of administration. The FDA has allowed all access ports for non-intraspinal delivery to be marketed under the prenotification (510(k)) provisions of the Food, Drug, and Cosmetic Act of 1938, as amended. Intraspinal drug delivery by access port requires premarket drug-device approval. Concerns about drug-device biocompatibility are not as important with the ports as with IIPs because of the limited time that the drug remains in the reservoir.

### Pulsative pumps

Pulsatile pumps are nonprogrammable, mechanical, hand-operated systems that are totally implanted subcutaneously. They incorporate a series of one-way valves that are manually compressed by the patient for bolus administration of a single drug. The dosage is adjusted by either varying the number of compressions or the concentration of active component of the drug. The pump is made of polysulfone and has a reservoir capacity of 12-15 mL. It can be used for patient-controlled bolus doses of opioids for intractable pain, (14). as well as insulin.

### Vapor-pressure powered pumps

First approved by the FDA in 1982, the vapor-pressure powered implantable pump is labeled for the following indications: in patients who require continuous hepatic artery infusions (CHAI) of floxuridine with bacteriostatic water of physiologic saline for treatment of unresectable tumors of the liver or colon (either primary or metastatic); and in patients who require anticoagulation with continuous intravenous (e.g., superior vena cava) infusion of herapin, who suffer from recurrent thrombophlebitis or pulmonary emboli when on oral anticoagulants.(15). This pump is unique in that it is powered by the vapor pressure of an inexhaustible flurocarbon charging fluid, freon, in a vapor-liquid mixture at normal body temperature and atmospheric pressure. The implantable components of the system include the pump itself, reservoir, and accessories that may include a micropore filter and various size catheters.

This nonprogrammable pump consists of a hollow titanium disc separated into two chambers by a metal bellows diaphragm, which serves as a flexible impermeable membrane. The dual-phase charging fluid is permanently sealed on one side of the diaphragm. The other side of the diaphragm serves as a refillable drug reservoir. The diaphragm exerts a constant pressure on the drug chamber (450 mm Hg) causing expulsion of drug from the reservoir through a 22 micro-outlet filter and flow-restricting capillary tube assembly to the patient.(10). Refilling of the drug chamber by percutaneously injecting the drug through a self-sealing septum causes the drug reservoir to expand, while simultaneously causing the fluorocarbon to condense into a liquid state, recharging the pump for the next flow cycle.

Several relative contraindications preclude its use in certain patients: those with severe psychiatric, emotional, or neurologic disturbances; persons whose body size is not large enough to accommodate the bulk and weight of the pump; and those who undergo frequent or long-term changes in altitude or engage in rough or vigorous occupations or activities, such as contact sports.(15). Each drug label dictates the contraindications and precautions associated with use of approved drugs in IIP.

Complications reported with the use of this vapor-pressure pump are attributable to the drug itself, the pump, and the accessories. They include, but are not limited to, pump pocket complications such as wound infections, skin necroses, seroma, abscesses; complications of hepatic artery infusion such as hepatic artery thrombosis,(16). duodenal atony,(17). chemical hepatitis, biliary sclerosis,(18,19). and biliary tract inflammatory responses; and systemic complications related to specific drugs, such as diarrhea, constipation, nausea, vomiting, somnolence, urinary retention, and various cutaneous reactions. Accessory equipment problems include catheter kinking, occlusions, and dislodgements.

### Peristaltic pumps

The FDA approved a programmable, peristaltic infusion pump in early 1988 for chronic intravascular (intra-arterial) infusion of floxuridine with heparinized bacteriostatic water or physiologic saline for palliative management of unresectable tumors of the liver or colon.(15). This pump was also approved at the same time for systematic intravenous infusion of doxorubicin with bacteriostatic water or physiologic saline for palliative management of various solid tumors, lymphomas, and leukemias.

In 1991, the pump was approved for epidural administration of preservative-free morphine sulfate solution for the treatment of chronic intractable pain of malignant or nonmalignant origin, and for intrathecal (subarachnoid) administration of preservative-free morphine sulfate sterile solution for the treatment of chronic intractable pain of malignant or nonmalignant origin. In 1992, intrathecal baclofen was approved for use with this pump for management of severe spasticity of spinal cord origin for patients unresponsive to oral baclofen or who experienced intolerable central nervous system (CNS) side effects at clinically effective doses.

The implantable components of the system are the pump, which includes a radiofrequency receiver and battery, vascular catheters, optional access port, connectors, and a variety of catheter accessories. The lithium and thionyl chloride battery power the pump and each model dispenses drug in accordance with information transmitted from a hand-held external programmer. The pump consists of: an 18 mL collapsible, seale, titanium drug reservoir that can be filled percutaneously through a self-sealing septum; an optional 22 micro-bioretentive filter; and a rotor, driven by a stepp motor through a gear train, attached to several rollers that compress a flexible U-shaped tube and force the drug through a delivery catheter. The step motor, controlled by the hand-held programmer, controls the flow rate of the drug. The programmer, placed over the implanted device to provide a magnetic field, transmits radiofrequency signals that record patient identification, date, current prescription, drug name, concentration, dose rate, infusion mode (five choices), reservoir volume, alarm settings and status. All models are programmed with an audible alarm system that warns the user of low battery power, low reservoir volume, and pump memory error. The battery has an expected life of several years. Accuracy is reported to be within +/-10-15 of the programmed flow rate under a variety of conditions. (14,20).

The pump is contraindicated in the presence of infection, when it cannot be implanted less than 2.5 cm from the skin surface, when the patient has another implanted programmable medical device, or in those whose body size is not sufficient to support the bulk and weight of the pump. Each drug label dictates the contraindications and precautions associated with the use of this drug-device delivery system.

## Clinical Effectiveness

### Intrahepatic chemotherapy for metastatic colorectal carcinoma

The age-adjusted incidence, mortality, and 5-year survival rates for colorectal carcinoma in the US are 50.0/100,000, 19.6/100,000, and 58.4.(21).

The liver is the most frequent site for metastatic spread of this disease. Hepatic metastases are present in 18 of patients at the time of their primary tumor diagnosis and in 60 of patients who develop advanced disease.(22). Putative curative surgical resection (removal of all detectable gross tumor with negative margins) of metastases occurs in approximately 4-24 of patients. (23). For unresectable lesions, standard systemic 5-FU therapy produces response rates of 15-20. The survival time for untreated metastatic disease ranges from a few months to 2 years, and depends on disease extension at presentation.

Continuous hepatic artery infusion (CHAI) of chemotherapeutic agents was first used clinically by Watkins in 1962.(24). Its use is based on the observation that hepatic metastases result primarily from vascular rather than lymphatic spread and that such metastases derive most of their blood supply from the hepatic artery.(25). Fluorouracil and floxuridine were both used initially but Ensminger et al(26). later demonstrated that hepatic extraction ratios (heptic arterial drug level minus hepatic venous drug level divided by hepatic arterial drug level) of floxuridine ranged from 94-99, while those of fluorouracil were lower (19-51). These authors also showed that floxuridine provided up to a 500-fold higher intrahepatic drug concentration than systemic agents.

Regional (hepatic) chemotherapy, by means of an external infusion pump and an externalized catheter fluoroscopically placed into the hepatic artery through the femoral vein or brachial artery, has been in clinical use for over 30 years. Complete and partial tumor response rates have ranged from 30-80, although these responses were based on biochemical, as well as radiographic evidence of tumor Survival was limited because of intrahepatic toxicities, marginal tumor response to fluorouracil, and extrahepatic metastatic progression (lung, brain, bone). Treatment failures secondary to catheter dislodgements, leaks, and kinks, as well as arterial embolization, made the safety and marginal effectiveness of this treatment a concern.

The advent of a completely implantable system (pump or access port and catheter) was believed to increase the safety and efficacy of this mode of therapy by reducing infections, catheter dislodgements, arterial thrombosis, and hepatic malperfusion. Fluorouracil and floxuridine have been used in combination with each other and with the addition of other cytotoxic agents such as mitomycin C or cisplatin, as well as in combination with systemic (intravenous) infusion of folinic acid with varying tumor response.(27). The therapeutic margin of these cytostatic agents is narrow, and toxicity is dose-dependent. Floxuridine dosages between 0.2 and 0.3 mg/kg/d are associated with frequent interruption or cessation of therapy, while dosages of 0.1 mg/kg/d are less likely to cause biliary toxicity.

Today, patients who are candidates for CHAI by implantable pump require intra-operative placement of the pump and hepatic catheters and must undergo extensive pre-and postoperative laboratory and vascular studies, including serial carcinoembryonic antigen (CEA) levels, liver enzymes, transfemoral arteriograms, and computed tomography (CT) scans. Prophylactic cholecystectomy and segmental devascularization of the distal stomach and duodenum are now performed to reduce biliary toxicity and to increase total hepatic perfusion.(28). Patients with variant hepatic artery architecture may require multiple, simultaneous catheter or pump insertions, ligation of the variant vessels, or construction of an arterial vessel with an autologous vein or synthetic vascular implant. A fluorescein scan of the liver intra-operatively and a scintillation scan of the liver post-operatively are required to confirm complete perfusion of the liver and the lack of extrahepatic (gastroduodenal) perfusion. Arterial angiocomputed tomography (AACT) has also been recommended for followup evaluation of intrahepatic drug delivery because of poor resolution from scintigraphy. Chemotherapy by IIP is usually not initiated until liver enzymes have returned to les than three times normal.

Several controlled clinical trials have been conducted to demonstrate the effectiveness and safety of CHAI by IIP for hepatic metastases from colorectal cancer by measuring survival, time to progression of liver disease, time to overall (or extrahepatic) disease progression, complications and side effects (Table 3). The comparative efficacy of these drug/device interventions has been difficult to asses because of varying efficacy definitions, unreported patient selection criteria, and crossover treatment designs. For example, one study(29). used a 50 reduction in CEA levels exclusively as a definition of partial response to floxuridine, while others(30). used 50-90 regression of measurable disease by CT scan.

Table 3. Studies of unresectable, metastatic, colorectal carcinoma with CHAI

| Martin(31). | Kemeny(33). | Lorenz(32). | Hohn(34). | Ramming(29
No. eligible/evaluable patients | 74/69 | 99/93 | 52/46 | 143/115 | 55
- CHAI only; - SYS only; - SYS+CHAI[*] | - 36; - 33; - NA | - 48/45; - 51/48; - 31 | - 26; - 20; - 20 | - 67/50; - 76/65; - 28 | - 55; - NA; - NA
Type of infusion device; - CHAI; - SYS | - PE,VPP; - bolus | - VPP; - VPP | - VPP; - bolus | - VPP | - VPP
Mean duration of implanted device | NS | NS | NS | NS | NS
Objective tumor response; - C/P/S/Pr; - CHAI only; - SYS only; - SYS+CHAI | - 48; - 21 | - 1/23/6/15; - 0/10/15/23 | - 1/12/9/4; - 0/13/5/2 | - 4/17/21/8; - 3/3/34/25 | - 0/4/36/15; - NS
Median survival time mo | 12/6/10.5 | 17/12 | 16/19.5 | 16.7/16.2 | 19.2
Median time from treatment to any disease progression in months(all). | NS | NS | 11 | NS | NS
- CHAI only; - SYS only; - SYS+CHAI | - 15.7; - 6.0 | - 11 (3-32); - 7 (2-12) | - 8; - 12 | - 13.2; - 6.7 | - NS
Mean time from treatment to death (all) | NS | NS | 17 | | 11.5
- CHAI only; - SYS only; - SYS+CHAI | - 12.6; - 10.5 | - 17; - 12 | - 19.5 | - 16.7; - 16.1
- Patients randomized; - Followup (range)/months | - yes; - (2-37) | - yes; - NS | - yes; - NS | - yes; - NS | - no; - NS
Performance status measured during study | ECOG | Karnofsky | NS | Karnofsky | NS
- No. biliary complications (%); - No. systemic complications (%); - No. pump complications (%) | - 26; - 30-45; - 10.5 | - 3; - 8; - 0 | - (50); - (25); - (11) | - (68); - (58); - (19.1) | - (78); - 0

* Patients were randomized to 5-fluorouracil treatment and crossed over to CHAI at disease progression.

CHAI = continuous hepatic artery infusion; SYS = systemic (intravenous) infusion of 5-fluorouracil or floxuridine; NA = not applicable; PE = peristaltic programmable implantable infusion pumps; VPP = vapor pressure powered implantable infusion pumps with floxuridine; NS = not stated; C= complete response (disappearance of all metastatic disease); P = partial response (measured differently by each authority) without new disease; S = stable disease; Pr = progression of intrahepatic or extrahepatic metastatic disease; ECOG = Eastern Cooperative Oncology Group performance scale.

In an early case series of 55 patients implanted with a vapor-pressure powered IIP, Ramming et al(29). reported that median survival time of all patients was 19.2 months from diagnosis of hepatic metastases to death, and survival time from pump implantation to death was 11.5 months. There was no difference in survival time between those initially treated with CHAI of floxuridine by IIP and those who had received previous systemic flourouracil treatment. Also, the time from diagnosis of metastases (less than 3, or more than 3 months) to pump implantation did not influence median survival (14 months, 21 months, respectively.) A significant difference in survival time from pump implantation to death was noted between those patients implanted before August 1983 (9.3 months) and those implanted afterward (15.2 months), although the clinical significance of this finding remains unclear.

Substantial local toxicity occurred in this group: gastric ulcers (13), gastric obstruction (2), duodenal ulcers (4), chemical hepatitis (13), and sclerosing cholangitis (2). Unfortunately, although there was no known extrahepatic disease at the time of implantation, distant metastases occurred in 34 patients undergoing IIP treatment.

Martin et al(31). reported that, despite a delay in intrahepatic tumor progression, disease-free progression and overall survival time did not differ between patients treated with bolus hepatic artery infusions (BHAI) of floxuridine by a programmable implanted pump and patients given intravenous fluorouracil. This prospective, randomized trial demonstrated a complete or partial tumor response of 48 in the BHAI group and 21 in the systemic group, as well as longer time to intrahepatic disease progression (15.7 vs. 6 months, respectively), but no difference in any-site (extrahepatic) disease progression (6.0 vs. 5.0 months, respectively) or survival (12.6 vs. 10.5 months, respectively). These authors believed that despite the lack of survival advantage, BHAI may be valuable if it improves the patient's quality of life. However, they found no difference between the two groups in weight gain, Eastern Cooperative Oncology Group performance scale, or symptoms, although the BHAI patients did report fewer side effects and more subjective satisfaction. Based on these findings, they concluded that they could not recommend BHAI since there was no difference in survival time to counterbalance the greater expense and morbidity associated with its use.

Regional (intrahepatic) chemotherapy trials were unsuccessful in demonstrating an effect on extrahepatic metastases and, therefore, survival time. Lorenz et al(32). attempted to demonstrate that extrahepatic disease progression could be slowed and survival prolonged, by also administering fluorouracil systemically to those patients receiving CHAI of floxuridine. They randomized 46 patients with unresectable metastatic disease to either CHAI of floxuridine (26) or CHAI of floxuridine and systemic fluorouracil (CHAI/S) (20) to see whether the addition of a systemic arm would influence extrahepatic disease occurrence and survival. The results demonstrated no difference between the groups in extrahepatic disease progression (16/26 vs. 12/20 patients, respectively), tumor volume reduction, response rate (partial response measured as a significant reduction in tumor mass by CT and more than a 50 reduction in CEA), or median survival time (16 months and 19.5 months, respectively). Addition of the systemic treatment arm did not significantly alter tumor progression, occurrence of extrahepatic disease, or survival.

Complications included three pump pocket infections requiring explantation in two patients. Catheter dislodgement and thrombosis in three patients prematurely terminated CHAI. Severe toxicity occurred in both the CHAI group and the CHAI/S group: chemical hepatitis (50, 40, respectively); biliary sclerosis (15, 10, respectively); gastrointestinal toxicity (15, 45, respectively); and nausea and vomiting (0, 25, respectively). The authors reserved judgment on the efficacy of this therapy and, because of safety concerns about toxicity associated with these two drugs, concluded that CHAI should not be viewed as a primary treatment but should be reserved for further prospective studies.

In an attempt to determine differences in tumor response rates between intrahepatic floxuridine and intravenous fluorouracil, Kemeny et al(33). compared each drug's efficacy in 93 patients with colorectal adenocarcinoma and measurable liver metastases in a prospective, randomized trial. All patients underwent laparotomy for staging, confirmation of no extrahepatic disease, and intrahepatic artery catheter and IIP placement. Forth-eight patients were treated with CHAI of floxuridine by IIP and 51 were initially treated with systemic fluorouracil by IIP. In those patients randomized to systemic treatment, an access port was also implanted at the time of laparotomy, so that crossover to intrahepatic floxuridine would be possible at the time of disease progression. The IIP was connected to a cephalic vein catheter to administer the fluorouracil, and the hepatic artery catheter was attached to an access port until needed. Twenty-four of 45 patients in the CHAI group has a complete or partial response (1 complete, 23 partial); whereas, 10 of 48 patients in the systemic group, had a partial response (50 vs. 19.6, respectively). This study also demonstrated a significant tumor response in initially nonresponsive persons who crossed over form the systemic arm of the study to CHAI at the time of disease progression. Thirty-one patients from the systemic arm crossed over at that time to CHAI. The 20 patients who did not cross over the CHAI arm had a median survival time (from initial study entry) of 8 months (3.4 months from disease progression). Among the 31 patients who did cross over, median survival time was 18 months from initial study entry (9.5 months form disease progression and crossover). Although median survival time did not differ significantly between the two groups (17 vs. 12 months, respectively; p=0.42), median time to disease progression was significantly delayed in the CHAI group (9 months vs. 5 months, respectively; p = 0.016). Unfortunately, a determinative finding for the agent responsible for any of these subsequent responses was impossible because of the crossover design. No pumps failed, although poor catheter placement and migration occurred in three patients, one patient had pump pocket erosion, and seven catheter occlusions occurred in the systemic group.

In a protocol similar to that of Kemeny et al(33). , Hohn et al(34). randomized 143 patients to either floxuridine by CHAI or administered intravenously (superior vena cava) for treatment of metastatic intrahepatic colorectal cancer, to determine if any differences in tumor response occurred in the two groups. Disease ascertainment was not comparable between the two groups. The systemic group had their IIPs implanted under fluoroscopy, while the CHAI group had their IIPs implanted during staging laparotomy, underwent biopsy of suspicious lymph nodes, and had infusion pumps inserted even in the presence of extrahepatic disease. Initial intravenous dosages started at 0.075 mg/kg/d and were escalated until diarrhea developed. Initial CHAI dosages started at 0.3 mg/kg/d, but were reduced to 0.2 mg/kg/d because of hepatobiliary toxicity (200 of baseline alkaline phosphatase). Crossover was allowed from systemic treatment to CHAI at the time of disease progression. Mean time to intrahepatic disease progression, regardless of crossover, was 13.2 months in the CHAI group and 6.7 months in the intravenous group. Median time to disease progression was 5.5 months in the crossover group (28 patients). Mean survival time was similar in the CHAI and systemic groups (16.7 and 16.2 months, respectively). Because of early disease progression in the systemic group, the effect of CHAI or systemic floxuridine on extrahepatic disease progression was not determined.

Wagman et al(30). stratified 91 patients with histologically confirmed colorectal carcinoma with liver metastases according to tumor burden and resectability (A = solitary resectable metastasis, B = multiple resectable metastases, C = multiple unresectable metastases), and then randomized each of these three groups to either CHAI or, depending on their tumor load, observation, surgical resection, or systemic treatment with 5-FU, respectively (Table 4.). The purposes of this study were to measure the effect of CHAI when combined with surgical resection of metastases, to measure the difference in morbidity when CHAI is used after multiple hepatic resections, and, to measure whether, in patients not rendered disease-free at the time of laparotomy, CHAI improved survival or delayed progression of disease.

Table 4. Results for a series of patients with metastatic colorectal carcinoma of the liver randomized to treatment with continuous hepatic artery infusion of floxuridine or surgical resection(30)

A1-Solitary metastasis, resection only | A2-Solitary metastasis, resection + CHAI | B1-Multiple metastases, resection + CHAI | B2-Multiple metastases, CHAI only | C1-Multiple unresectable metastases, CHAI only | C2-Multiple unresectable metastases, systemic 5-FU and CHAI | CP-Multiple unresectable metastases, + portal nodes, CHAI only
No. of evaluable patients | 6 | 5 | 10 | 14 | 31 | 10 | 15
Objective tumor response C/P/M/Pr | 6/0/0/0 | 5/0/0/0 | 10/0/0/0 | 8/5/NR/NR | 1/17/NR/NR | 0/2/NR/NR | 0/5/NR/NR
Median time in months from treatment to disease progression (range) | 8.7(5.0-39.4) | 30.7 [*] (16.6-81.6) | 15.6 [**](4.0-63.3) | 9.4(4.6-50.8) | 8.8 [***;](0.7-49.7) | 7.5(2.0-31.6) | 6.0(0.4-19.9)
Median time from treatment to death (range) | 28.3(10.7-75.8) | 37.3(16.6-81.6) | 19.8(4.0-65.3) | 22.4 [****](14.7-50.8) | 13.8(0.7-62.6) | 11.6(2.0-39.3) | 9.0(0.4-34.6)
Cumulative survival (%) | - 1y; - 2y; - 3y; - 4y; - 5y | - 5(83.3); - 4(66.7); - 3(50); - 3(50); - 3(50) | - 5(100); - 4(80); - 3(60); - 2(40); - 2(40) | - 7(70); - 5(50); - 4(40); - 3(30); - 3(30) | - 14(100); - 6(42.9); - 2(14.3); - 1(7.1); - 1(7.1) | - 18(58.1); - 10(32.3); - 3(10); - 1(4.8); - 1(4.8) | - 5(50); - 3(30); - 1(10); - 0; - 0 | - 6(40); - 1(6.7); - 0; - 0; - 0
No. dead of recurrence (time from Tx in mo.) No. alive (mo. of followup) | 4(10.7, 15.5, 28.3, 75.6); 2 with disease (44.3, 44.5) | 1 (37.3); 2 of other causes (16.7, 35.1); 2 -no recurrence (64.4, 81.6) | 20/24 of B1 and B2 died of progression; 1 - no recurrence (50.8) | 2 died of sclerosing cholangitis (65.3, 18.2), 1 of sepsis with no recurrence (63.3) | 39 of all group C (C1, C2, CP) died of progressing disease | 1 died of MI; 1 of sclerosing cholangitis intra-operative | 14; 1 intra-operative death

* (p = 0.03)

** (p = 0.18)

*** (p = 0.94)

**** (p = 0.42)

CHAI = continuous hepatic artery infusion; 5-FU = 5-fluorouracil; C = complete response (disappearance of all metastatic disease); P = partial response; M = mild response; Pr = progression of intrahepatic or extrahepatic metastatic disease; MI = myocardial infarction; NR = not reported; Tx = treatment

CHAI = continuous hepatic artery infusion; 5-FU = 5-fluorouracil; C = complete response (disappearance of all metastatic disease); P = partial response; M = mild response; Pr = progression of intrahepatic or extrahepatic metastatic disease; MI = myocardial infarction; NR = not reported; Tx = treatment

As expected, patients in the group with solitary, resectable metastases showed the best median survival over the other two groups (A = 37.3 months, B = 22. 4 months, C = 13.8 months). The authors demonstrated a significant difference in survival time between the stratified groups with A over B and C (p = 0. 03, 0.002, respectively) as well as a significant difference between groups B and C (p = 0.06). However, there were no differences in survival time within group B (p = 0.42) or group C (p = 0.55). Disease progression in those patients with solitary lesions who were treated with CHAI and resection (groups A2 and B1) was delayed significantly vs. those treated with resection only (p = 0.03), and to a lesser extent, with CHAI only (p = 0.18). No difference was found in time to disease progression in patients with unresectable metastases (with or without portal nodes), despite treatment with CHAI, fluorouracil, or both.

These five prospective, randomized studies assigned patients to treatment with CHAI of floxuridine by IIP or alternative therapies, ranging from intravenously administered floxuridine or fluoruracil, surgical resection, or no treatment. Overall response rates to floxuridine by IIP (complete and partial) ranged from 42-64, while median times from treatment to death ranged from 12.6 to 17 months in the floxuridine groups and 10.5 to 19.5 in the systemic groups (including crossover patients), although overall survival time did not differ between those treated with floxuridine by IIP and other treatments. Extrahepatic progression of disease was not influenced by CHAI, but intrahepatic disease was slower to progress in patients treated with CHAI of floxuridine.

One factor that may influence the therapeutic effectiveness of CHAI of floxuridine by IIP is the ability of the drug to continuously perfuse the liver and metastases in adequate concentrations over the course of the treatment period. Safi et al(35). evaluated the results of AACT retrospectively in 82 patients with mixed metastatic hepatic disease (carcinoid, squamous cell, neurosarcoma, and colorectal), including 6 patients with extrahepatic metastases. Despite a difference in perfusion patterns (70 homogenous, 24 heterogenous, 6 incomplete) of the liver and metastases (16 total and 84 peripheral) with CHAI of floxuridine, the complete and partial response rates of patients with homogeneous perfusion of both hepatic lobes were identical (57) to the response rates in patients with inhomogeneous perfusion patterns (55). Patients with colorectal metastases with both homogeneous and inhomogeneous perfusion on their AACT (n = 69) demonstrated a complete response in 20, a partial response in 19, stable disease in 17, and progression in 18.

The median duration of response was similar among those with complete, partial and stable disease (15, 14, and 15 months, respectively). The 1-, 2-, and 3-year survival rates for patients with colorectal metastatic disease were 80, 45, and 20, respectively. The median survival time was 20 months; 27 months for responders, 10 months for nonresponders (p<0.01). The pretreatment metastatic tumor volume (MTV) of the liver in each patient was measured and compared to response rates to CHAI. Before therapy, 23, 25, 21 patients, respectively, had <25, 25-50, and >50 MTV, and their respective response rates (complete and partial) were 62, 68, and 43. The authors concluded that, in the presence of complete metastatic perfusion, response to regional chemotherapy was not related to MTV or the perfusion pattern of the metastases but to the direct response of the tumor cells to floxuridine. They also concluded that AACT use permits precise assessment of CHAI at the time of pump placement and subsequently. The response rates in this retrospective report are comparable to those of the previously discussed prospective trials.

A comparison of these results with those of two studies that employed implantable access ports to administer floxuridine demonstrated comparable complete and partial responses to chemotherapy, despite retrospective evaluation and biased designs. Civalleri et al(36). reported on 39 patients with primary or metastatic hepatic carcinoma who underwent treatment of CHAI with either an IIP (22 patients) or an access port and EIP (17 patients) with programming capabilities comparable with those of the IIP. The two drug-delivery systems were evaluated for comparability in terms of implant duration, number of treatment cycles administered, and complications. All patients were intra-operatively staged and had a CHAI catheter inserted under direct vision. The authors do not state how the patients were chosen for either device. Post-operatively, they were evaluated by physical examination every 2 weeks and arterial perfusion scan every 3 months. Mean followup was 9.4 months in the implantable pump group and 7.0 months in the port group. The total number of treatment cycles was 130 in the pump group (mean = 5.6), and 66 (mean = 3.6) in the port group. After 10 months, 46 (10/22) of the patients were alive with a functional IIP; 58. 8 (10/17) were alive with a functional port; 3 patients were alive without any device and 15 patients had died of disease progression. There were more complications in the pump group (15 vs. 9). Treatment was stopped for access-related complications in 18.4 of the IIP group and 29.4 of the access port group.

Tuchmann et al(37). treated 36 patients between 1983 and 1988 using implantable access ports and EIPs, in a protocol that delivered floxuridine at a rate of 0.3 mg/kg/d for 14 days and saline for 14 days. Twenty-three patients were evaluable at 6 months for duration of survival, clinical condition, CEA levels, and size of tumor by ultrasound or CT. Ten of the 23 responded (response was defined as either a 30 reduction in CEA, and/or a 50 reduction in tumor volume as determined by ultrasound or CT), while in 6 patients disease progressed, and 7 patients had stable disease. Mean survival time was 13.1 months (range: 2-27), while the interval between the initiation of chemotherapy and relapse (time to progression) was 10.6 months (range: 6-16). The survival results and response rates in these two studies are similar to those reported in the prospective clinical trials above.

The National Institutes of Health (NIH)(38). informed OHTA that while several randomized trials have demonstrated superior response rates (usually partial) for CHAI vs. systemic fluorouracil, no trial has demonstrated advantages in survival or time to disease progression. Little if any advantage results from shrinkage of hepatic metastases in otherwise asymptomatic Considerable morbidity is associated with the placement and long-term presence of CHAI devices, and increased hepatic toxicity is observed from CHAI infusion compared with intravenous therapy. In the absence of demonstrable benefit in terms of survival of quality of life, and particularly considering the cost, this practice is difficult to defend. "At the present time this approach is still considered a potentially promising one, but it still is an investigational approach that cannot be recommended outside the clinical trial setting."

Overall initial response rates (complete and partial) to intrahepatic chemotherapy in patients with unresectable, metastatic hepatic disease ranged from 42-64 (EIP with an access port, and IIP), while median times from treatment to death did not differ significantly in patients treated with CHAI or systemic drugs. Extrahepatic progression of disease was not influenced by CHAI, although intrahepatic disease was initially slower to progress in patients treated with CHAI.

What data are available to compare implantable and external infusion devices, in terms of tumor response, progression, and survival, indicate that the rate-limiting factor is not the infusion delivery system, per se, but the cytostatic effect of the drug.

In these studies, moderate to severe complications occurred, most commonly, chemical hepatitis (a tripling of SGPT and bilirubin), seen in over 50 of all CHAI-treated patients.(18). The most serious and irreversible complication was biliary sclerosis (narrowing of the biliary ducts and secondary rise in alkaline phosphatase), which has been associated with higher dosages of floxuridine (0.3 mg/kg/d), and has been reported to occur in 5-60 of patients.(17,39,40). Other complications include partial or complete thrombosis of the hepatic artery, leakage of drug from the artery causing gastritis, duodenitis, ulcers, occlusion of the catheter, catheter displacement, and hemorrhage.(18,26,41). Gastrointestinal complications (nausea, vomiting, diarrhea) occurred in 6-90 of enrolled patients.

In the early clinical trials that utilized implantable pumps for chemotherapy, not all the patients underwent catheter tunneling. This was presumably responsible for a large percentage of early failures due to catheter kinking, migration, and their sequelae. Technical complications of the IIP and delivery catheters, such as leakage and kinking, have been ameliorated by redesign of the pump and catheter connections, by open surgical techniques for placement of the pump and catheter, and by concurrent prophylactic surgical procedures such as cholecystectomy and gastroduodenal devascularization. Except in the early experiences reported in CHAI therapy, complications requiring explantation of an infusion pump were infrequent. Other complications related to implantation of the infusion pumps were seroma and localized infection.

Methodologic issues may have obscured significant outcome findings or biased the study: nonuniformity in disease staging (noninvasive vs. intra-operative), inadequate sample size (power) to detect a difference in outcomes, and crossover of treatment upon disease progression to alternate treatments (from systematic chemotherapy to CHAI). When cytotoxicity caused dosage reduction, the differences in the calculated and actual dose administered were not reported in most studies. Finally, investigators used various definitions of complete and partial response to chemotherapy, which made comparisons of outcome difficult, if not impossible.

The costs of pre-operative angiography, prophylactic cholecystectomy, and gastric devascularization, and frequent laboratory and radiologic postimplantation studies, as well as additional expenditures associated with reoperation for complications or explantation of the infusion pump, must be balanced with the expectation of limited palliation and no benefit of increased life expectancy in these patients.

### Intraspinal morphine for chronic pain

Intrathecal morphine administration was first attempted in 1977 and, since clinical introduction of the implantable infusion pump in 1982,(42). has been used to treat pain of malignant origin. Morphine injected into the cerebrospinal fluid (CSF) creates a reservoir of drug that diffuses passively into the dorsal horn of the spinal cord, binds to opiate receptors, hyperpolarizes the interneurons and inhibits release of neurotransmitter substance P,(43). which inhibits pain transmission at the spinal cord level. Morphine is cleared from the CSF by diffusion along the neuraxis, by vascular absorption, and by rostral spread from the subarachnoid space to the supraspinal cisternae. (44). Its analgesic effect depends on the drug concentration near the receptor, on receptor response to drug stimulation, and on the number of opioid receptors available.(44). Morphine and other opioids are reversible with the use of narcotic antagonists.

Morphine injected into the epidural space produce analgesia by two mechanisms.(45). Initially some of the drug crosses the dura mater to enter the CSF. From there, it penetrates into the dorsal horn of the cord, similar to an intrathecal injection. At the same time, extradural drug is absorbed systemically, producing a plasma profile that resembles an intramuscular injection. Analgesia is produced as the drug is distributed to both the brain and spinal cord.

Although morphine has been approved for both intrathecal and epidural administration to alleviate chronic malignant pain and pain of nonmalignant origin, the choice of one route over the other depends, in part, on the skill of the pain specialist in locating the epidural or subarachnoid space. Another consideration is the anticipated duration of catheter implantation. Fibrous reactions and dural thickening have occurred with prolonged exposure to epidural catheters,(46). and are thought to be influenced by the catheter material and drug preservative. One advantage of the epidural route is the ability to control the level of sensory blockade.

The intrathecal route allows drugs to be deposited directly into the CSF, near the spinal cord receptors, resulting in a more rapid onset of action and a lower dosage requirement than the epidural route (approximately one-tenth to one-third the epidural dose).(47).

No controlled studies have been published that compare the effectiveness of intrathecal and epidural opioid use in chronic pain. However, Nitescu et al(48). studied 25 patients with advanced cancer pain who, while receiving epidural morphine and bupivacaine, experienced severe pain, as well as intolerable side effects from systemic and adjuvant analgesics. The purpose of the study was to assess comparative efficacy of the epidural and intrathecal routes by measuring the total amount of analgesics given by all routes to bring pain relief to an acceptable level. Both epidural and intrathecal drug delivery was accomplished by bolus doses through percutaneously inserted catheters. Total analgesic effect (all systemic, adjuvant, oral, and intraspinal drugs delivered), responses to visual analog scales (VAS) for pain, and changes in daily activities and sleep patterns were recorded. Total analgesic drug use during epidural administration of morphine and bupivacaine was assessed retrospectively, and evaluated prospectively during the intrathecal phase of the study.

As expected, the intial intrathecal dose that effectively controlled the pain was significantly lower than previous epidural doses in the same patient. This effect lasted up to 1 week for intraspinal morphine and bupivacaine, and 6 months for total analgesic use. Lower drug volumes and higher drug concentrations were needed with intrathecal delivery. Median daily effective doses of intrathecal morphine and bupivacaine were somewhat stable for the first 4 weeks of administration (15-17 mg/d), although 9 of the 25 patients were no longer in the study by this time. By 3 months, the remaining 10 patients were receiving median effective doses in the range of 38-40 mg/d, and at 6 months the 4 remaining patients were receiving median doses of approximately 100 mg/d.

In 1987, Ventafridda et al(49). analyzed the results of 37 papers published from 1979-1985 that reported on the efficacy of intraspinal morphine in pain of malignant origin. Three hundred and six patients had epidural infusions (21, implantable pumps; 79, external pumps attached to an externalized epidural catheter) and 107 had intrathecal (ubarachnoid) infusions, (76, implantable pumps; 24, external pumps attached to an externalized intrathecal catheter). They reported that the implantable pumps were used for a longer period of time, and that fewer side effects (drowsiness, sweating, itching, nausea, vomiting and urinary retention) were recorded for the epidural group. In their own study of 75 patients who received either intrathecal or epidural infusions, they concluded that patients who do not obtain adequate pain relief from oral morphine cannot develop adequate pain control by either epidural or intrathecal morphine because of other reasons for the pain, such as movement, deafferentation, or spinal cord compression. No evidence was presented to support this conclusion. They recommended EIPs for those patients with diffuse pain who respond to either intrathecal or epidural opioid treatment who are intolerant of oral and parenteral narcotics, and who have a short life expectancy (less than 6 months), and implantable systems for comparable patients whose life expectancy is greater than 6 months. Further, they recommended other concurrent routes of administration for opioids which contribute to the overall clinical management of pain.

Hassenbusch et al(50). 69 consecutive patients over a 6-year period in a prospective case series with administration of continuous, constant-rate infusions of epidural morphine by IIP to patients with terminal cancer. A temporary percutaneous epidural catheter was inserted for 2 -4 days and continuous morphine was infused. Visual and verbal analog pain scales, drug diaries, and complications were used to measure the effectiveness of pain control. Significant pain control was defined as at least a 30 reduction in pain analog values at epidural morphine dosages less than 40 mg/d. Forty-one of the 69 patients were implanted with a permanent system, and 37 of them were evaluable. No information was reported on the 28 patients who did not receive the permanent system, or on the 4 who were alive but unevaluable after 1 month in the permanent-system group.

Systemic use of morphine was reduced after 1 month from 77.7 +/-19.1 mg/d to 16. 1 +/-3.6 mg/d, but rose to 27.9 +/-2.6 mg/d after 9 months. The mean epidural dose of morphine after 1 month was 20.7 +/-2.6 mg/d, rising to 49.3 plusmn; 9.9 mg/d after 9 months of infusion. Responses on the pain VAS decreased from a mean of 8.6 +/-0.3 before epidural infusion to 3.8 +/-0.4 after one month. At 1, 3, and 6 months, satisfactory pain relief was obtained by 87.1, 81, and 81.2 of the 41 patients, respectively. Ten infusion system complications were reported, ranging from catheter migration to superficial wound infections, along with three complaints of voiding disturbances. One patient was suspected of having drug tolerance after 24 months, but further examination showed aggressive extension of the underlying pelvic cancer. The mean survival time in this series of patients was 7 months (range not reported).

Onofrio et al(51). evaluated 53 terminal cancer patients with unacceptable side effects (somnolence) from parenteral narcotics, and measured the efficacy (quantity of drug, mobility, pain relief) of intrathecal morphine. Although these authors did not find any association between analgesic effect and age, mobility, prestudy analgesic drug use, or prestudy duration of pain, all patients had significant pain relief at 4 weeks. The intrathecal dose of morphine increased two to threefold within the 16-week study period. Pain relief experienced from the preimplantation bolus dose of intrathecal morphine was the only parameter predictive of long-term efficacy. Patients also received systemic (intravenous) analgesics during the study period, possibly masking or confounding any effects, or lack thereof, attributed to the epidural route.

Penn and Paice(52). studied 43 patients, 35 with pain of malignant origin and 8 with chronic nonmalignant pain (CNMP), and attempted to demonstrate that early treatment of pain with intrathecal morphine would be effective. Objective measurements included systemic drug use and activities of daily living (ADL): Twenty-eight of the 35 cancer patients manifested improved pain management, 3 were classified as treatment failures, and 4 had a poor response. The eight patients with CNMP all had a good or excellent response. The mean followup period was 21 months.

The use of access ports also has been evaluated in the treatment of chronic pain. Madrid et al(53). treated 100 cancer pain patients who were opioid-naive with morphine via access port and a lumbar intrathecal catheter. No concurrent systemic drugs were administered during the study period. The purpose of the study was to evaluate the safety, feasibility, and long-term effectiveness (greater than 3 months) of morphine administered outside the hospital. All had good pain control but 28 complained of urinary retention and 13 of pruritus. Catheter occlusions developed in 8 of the patients and CSF fistulae occurred in 4.

Gourlay et al(54). treated 29 patients with terminal cancer in whom oral opioids with adjuvant drugs no longer provided effective pain relief. After a 2-day trial of epidural morphine, the patients were randomized to receive either intermittent bolus doses of epidural morphine via access port or continuously infused epidural morphine by IIP. Effectiveness measures included VAS, a categorical scale to measure pain relief, problems with the device, and recommendations. Dosage adjustments were made according to patient responses to these and other psychometric results. When a patient's morphine requirements exceeded the maximum delivered by the pump, the route of administration was changed to intrathecal (10/28 patients). The mean duration of implantation was 140 days (range 28-378, median 100) for the access port group and 169 days (range 6-537, median 100) for the infusion pump group. The VAS scores, and the categorical scores were equivalent in both groups. No significant differences were found in any of the measured parameters. Both groups required more drug over time, with significantly greater dosage escalation in the continuous infusion group.

Crul and Delhaas(47). described their 5-year experience in treating 140 cancer patients with intraspinal morphine via an implanted access port. One hundred and ten patients with a short life expectancy were offered an epidural catheter, and the 30 others an intrathecal catheter. Both tunneled catheters (20 epidural and 30 intrathecal) and transcutaneously inserted catheters (90 epidural) were used. While the epidural group was complication-free during the first 3 weeks, 23 patients (25) with transcutaneous catheters experienced catheter dislocation, necessitating removal or replacement.

The most frequent complication in the intrathecal group was CSF leaks (26.6), occurring early in treatment. A significant difference in the incidence of complications arose between the epidural and intrathecal groups within the first 3 weeks of treatment, 8 vs. 25, respectively (p = 0.02). During the remainder of the treatment period (20-366 days), epidural complications rose to 55 and intrathecalones dropped to 5.

Among the 110 patients with epidural catheters inserted, 121 major complications (dislocation, obstruction, infection) were reported in the transcutaneous catheter group (90 patients) and 7 were reported in the 20 patients with a tunneled catheter. Thirty patients with tunneled intrathecal catheters had fewer major complications.

Auld et al(55). evaluated patients with CNMP to determine patient selection criteria for intrathecal narcotic delivery. Patients underwent a trial epidural bolus morphine injection to measure effectiveness (phase 1). If they experienced good to excellent pain relief, an access port and epidural catheter were implanted (phase 2). They were stabilized over 4-12 weeks, and if they continued to have good pain relief, were implanted with a vapor-pressure powered infusion pump (phase 3). Serum morphine levels, pain medication log, patient pain assessment, and serial ADL measurements were all used to define effectiveness. Sixty-two patients entered phase 1; 37 entered phase 2; and 32 entered phase 3. The 30 patients who did not complete the trial dropped out because of incomplete pain relief or relief of too short a Seventeen of the 32 patients who entered phase 3 had recurrent pain during the 24-month trial.

Coombs,(56). in a study reported in 1983, attempted to compare the effectiveness of epidural morphine in five patients with CNMP and five patients with chronic intractable pain secondary to adenocarcinoma. Measures of effectiveness used were the McGill Pain Questionnaire, VAS, drug diaries, Zung Depression Scale, and a trial of cognitive drills. The CNMP patients reported more pain during baseline that the cancer patients, and less relief of pain at the 12-week evaluation. Tolerance developed in all patients. Four of the five CNMP patients showed no improvement in cognitive skills during the trial.

With regard to the use of infusion pumps for management of chronic pain, NIH has stated that there are limitations on the conclusions that can be drawn from the data. For example, the studies do not give information about disease status or progression during the trial; there is no information regarding patients who discontinued treatment; there are no direct comparisons of effectiveness of intraspinal morphine vs. other delivery systems in matched subjects; no discussion is present regarding patient satisfaction data nor the incidence of side effects. "These limitations preclude a definitive answer to the question of clinical effectiveness of external and implanted infusion pumps for the management of cancer pain. "

At the same time, there is a belief among some experts in cancer pain management that "a small proportion" of pain patients may obtain substantial relief from epidural or intrathecal administration of opioids. An example of the prevalence of this group of patients was cited from the study of Hogan et al(57). in which 12 of 1,205 cancer patients achieved pain relief with epidural morphine or morphine plus bupivacaine.

Nonetheless, these authors stated that data are insufficient to determine whether these techniques should be used in a more widespread fashion in patients with cancer. Randomized studies comparing chronic systemic treatment to spinal infusion would be necessary to determine the cost-benefit ratio from more widespread use of these methods. Similar arguments hold for use of these methods in nonmalignant conditions.

Measures of the effectiveness of intrathecal or epidural morphine included subjective quantification of pain reduction with VAS, drug diaries, and correlations between plasma opioid level and VAS. In the studies reviewed , short-term (within 4 weeks) good to excellent pain control was achieved with intraspinal narcotics, systemic opioids and/or other analgesics, or a combination of these. Total analgesic drug use (all routes) decreased initially in all studies, and slowly escalated over time. Only one study(54). utilized drug exclusively by the epidural route and demonstrated excellent pain relief in narcotic-naive patients. Serum and CSF morphine levels did not correlate at all with subjective measures of pain relief (i.e., VAS), while activities of daily living, concurrent systemic drug use, and changes in patient mobility reflected patient response.

All of the studies demonstrated increased total analgesic use over time. At 5 months or longer, the intraspinal mean analgesic equivalent dose had increased to more than three times the initial effective dose. "Morphine holidays" with adjuvant drugs such as bupivacaine were successful in treating patients who experienced acute drug escalations, and these holidays enabled successful resumption of morphine at much lower dosages. Other authors reported a change from epidural to intrathecal routes to treat dosage escalations that would have required drug delivery rates beyond the capability of the pump. Whether these escalations derived from underlying disease progression (particularly in oncology patients), tachyphylaxis (tolerance), or device failure was not determined in all cases. In CNMP patients, the drop out rate was high owing to insufficient pain relief, dissatisfaction by the patient, or tolerance.

Foley(58). classified cancer pain into five types: acute, chronic, chronic nonmalignant pain in patients with cancer pain, cancer pain in the presence of illicit drug addiction, and pain in dying patients. This classification system enables health care practitioners treating patients to acknowledge both the acute and chronic aspects of mixed pain syndromes, and assists them in treating not only the underlying cause of the pain, but also the attendant psychological or social consequences of their pain. Patients with chronic, nonmalignant pain, including neurogenic or idiopathic pain, present different management issues,(59,60). such as tolerance, drug dependence (addiction, physical dependence), undertreatment of pain, and availability of opioids for bona fide medical uses.

It is recommended that treatment regimens for chronic pain be effectively tailored to the individual patient(61). by evaluating: (1) the natural history of the malignancy or underlying lesion; (2) the patient's physical and psychological condition, including pulmonary function tests and evaluation of general mobility; (3) the locations, intensity, and mechanisms of the pain and the types of responses to previous pain relief therapies and regimens; (4) the drugs, medical devices, and other resources available to the patient; (5) the knowledge and skill of the personnel available to apply each method most effectively; and (6) the decision of the patient to undertake a particular regimen, given the benefits and risks of that regimen, and the patients cooperation with the caregivers.(62,63). The information elicited in this evaluation can be utilized to effect a coordinated, multidisciplinary approach (neurosurgical, anesthesia, behavioral and pharmacologic therapies) for chronic pain treatment.(58).

In virtually all of these studies, little information was reported on why patients dropped out during the trial period. No objective data were provided about treatment responses or reasons for going off protocol. These factors remain a critical impediment to understanding the overall effectiveness of intraspinal morphine in eligible patients and to recommendings its widespread use.

The studies of the effectiveness of intraspinal morphine for chronic pain (whether of malignant or benign origin) highlight the progression of analgesic therapy in patients with chronic pain syndromes, and also point out some of the difficulties in measuring the effectiveness of pharmacologic interventions for pain relief. Individual patient response to an acute intraspinal trial administration of opioids was the single most predictive measure of short-term (4 weeks) effectiveness of morphine.

### Intrathecal baclofen for chronic spasticity

Chronic spastic syndromes, a heterogenous group of clinical entities, are sequelae of upper motor neuron damage such as spinal cord trauma or multiple sclerosis. They may manifest in painful involuntary hyperactive monosynaptic and polysynaptic reflexes with accompanying hypertonic increases in muscle tone.(64). The antigravity muscles (arm flexors and leg extensors), are predominantly affected by exaggerated tendon reflexes. At rest, the muscles are flaccid and electromyelographically silent. If the muscles are stretched rapidly, a "clasp-knife" phenomenon develops, in which initial movement of the limb is abruptly halted almost in a locked position. Continued passive extention or flexion slowly dissipates this resistance, and full range of motion is possible.

Maynard et al,(65). in an epidemiological study that measured incidence of spasticity after traumatic spinal cord injury in 100 patients, reported that spasticity developed in 67 of patients by the time of hospital discharge (mean days to discharge 118 +/- 7.4).

Treatment regimens for spastic patients are often difficult because of the elapsed time since the onset of injury, the extent of the spinal cord lesion, and other accompanying disabilities such as dystonic posturing, synkinetic movements, flexor spasms, and the fact that some treatments often mask residual voluntary motor movement. (66). Treatment is centered around the preservation of the remaining neurologic function, and ablation or control of painful or debilitating flexor spasticity.

Since the 1950s, treatment for spasticity has included a variety of invasive surgical procedures, such as spinal cord stimulation with implantable, epidural electrodes,(67). deep brain and cerebellar stimulation,(68). and selective peripheral neurotomies,(69). to interrupt the spinal reflex arc or reduce afferent neuronal stimulation of the dorsal horn.(70). The sequelae of these surgical procedures and medical therapies have induced disabilities such as bladder dysfunction, partial paresis, sensory loss, drowsiness, hallucinations or loss of voluntary motor control. These treatment options are often combined with the use of oral antispasmodic agents such as baclofen and other oral agents such as morphine, fentanyl, benzodiazepines, or dantrolene to control the severity and pain of spasms.

The effectiveness of intrathecal baclofen for the control of spasticity was first shown in 1984 and relevant clinical studies are reviewed.

Penn et al(71). in an open-label, compassionate-use protocol investigated 66 consecutive patients (32 with spinal trauma, 33 with multiple sclerosis, and 1 with lateral sclerosis) with intractable spasticity, who had failed oral antispasmodic therapy. All patients who consented underwent a screening procedure, as follows. An intrathecal catheter was inserted percutaneously under fluoroscopy into the lumbar subarachnoid space. Incremental bolus doses of baclofen were administered (25 to 100 micro-g) over a period of days to weeks to judge efficacy of intrathecal administration before the implantation of a permanent delivery system; to test individual drug tolerance; and to fix the baclofen dosage effective for 8 to 12 hours in order to optimize the drug administration schedule. This study employed a randomized, placebo-controlled crossover design, allowing patients to act as their own controls. If there was no effect on spasticity, measured as a reduction in the intensity and number of spasms, or if someone did not experience the anticipated relief from spasticity or pain, or refused further treatment with intrathecal baclofen,; that person was considered ineligible for the chronic phase of the study, and those who failed to pass the screen were not evaluated in measurement of the effectiveness of baclofen.

Once successfully through the screening period, 62 of the 66 patients had an implantable infusion delivery pump inserted subcutaneously, attached to the previously implanted intrathecal catheter. Patients were evaluated for changes in muscle tone, frequency of muscle spasms, reflexes, electrodynamic studies of lower extremity muscle groups, induced spasms, and voluntary control of the lower extremities. The mean treatment period was 30 months (range 3 -84); median length of treatment = 27 months; mode = 8 months. Sixty patients had good relief of spasticity. It required 18 to 24 months of escalating baclofen doses to gain food control over muscle spasms. The mean preimplantation Ashworth (spasticity) score declined from 3.8 to 1.4 postimplantation. Spasm frequency scores also dropped from their preimplantation levels. Three patients had recurrence of spasms at 2, 3, and 3.5 years of intrathecal baclofen infusion. Two patients withdrew (time not reported) because they wanter more extension rigidity for standing. Four patients died of underlying disease progression.

The 62 patients were implanted with a total of 91 infusion pumps. Nine of these pumps failed (including early prototype models). Catheter complications occurred with "unfortunate regularity" (5 punctures, 11 kinks, 3 dislodgements, 4 disconnections, 2 breaks). Intrathecal baclofen infusion was restored in all patients by replacing the catheter. Five surgical complications required either explantation or reimplantation of a pump. Four infusion pumps stalled, requiring removal and reimplantation.

Several different transient side effects were reported in 31 patients, primarily due to baclofen overdose. All side effects resolved by reducing the dosage. One patient with multiple sclerosis developed grand mall seizures after several months of intrathecal baclofen and was treated with chronic anticonvulsant therapy. Varying degrees of effectiveness were found in 97 of the patients in this series. The two failures were one patient each with multiple sclerosis and lateral sclerosis. The infusion pump had a failure rate of 7, while catheter complications that required interruption of drug delivery occurred in over 50 of the

Lazorthes et al,(72). in a protocol similar to that of Penn, treated 18 of 38 patients (6 with multiple sclerosis, 8 with trauma, and 4 with cerebral vascular disease) at home with intrathecal baclofen by either access of port or IIP. The other 20 were not treated because of significant ineffectiveness of intrathecal administration, overeffectiveness (loss of useful extensor rigidity), difficulties in followup, and patient refusal. The effectiveness measures used were the Ashworth scale, motor performance scale, and neurophysiologic assessments. Fourteen of 16 patients showed improvement in the occurrence of painful muscle spasms. Functional improvement varied. Moderate to good and lasting improvement occurred in 12 patients. In the remaining six patients, five of whom had multiple sclerosis, spasticity was reduced but there was no functional improvement. The longest followup in this study was 18 months (two patients). The treatment effect (either preservation of residual spastic function in patients with some useful functional motor activity, or total antispasticity in patients without any motor activity) required careful drug titration to reach an effective therapeutic dose. From the titration period to the end of followup, the mean daily effective dosage of baclofen (90 micro-g, range 15-250 micro-g) doubled (range 26 to 500 micro-g). The question of long-term tolerance was not addressed by this study design, although the trend certainly demonstrated increasing dosages over the 18-month period. Device complications included three catheter dislodgements, and one pump failure requiring explanation. The four cases of local sepsis and the three incidents of purulent meningitis were seen in patients implanted with an access port. The need for daily percutaneous refilling in immunosuppressed individuals convinced the authors to abandon access port insertions in favor of IIPs. Severe drug complications occurred in two patients from drug overdose, requiring resuscitation and artificial ventilation in one of them.

Loubser et at(73). evaluated patients with refractory spasticity for long-term rehabilitative issues and for tolerance. After weaning from all previous medication, 9 out of 10 eligible male patients had an intrathecal catheter inserted and were randomized, in 12-hour intervals, to receive either continuous baclofen or placebo for spasm and reflex control. Muscle tone, frequency of spasms, urodynamometry, reflexes, pulmonary function, brainstem auditory-evoked potentials, functional abilities, and personal independence were assessed every 12 hours. Ashworth scores declines in 7 out of the 9 patients during the placebo period (p = 0.02), while 6 of 9 reflex scores decreased during the same period (p = 0.001). During the period of baclofen administration, Ashworth and reflex scores declined significantly in all patients (p = 0.01). Eight of the 9 patients improved in independence and functional status. During the second phase of this study, a permanent infusion pump was implanted in seven out of the nine eligible patients (two elected not to proceed). Four patients experienced a decrease or withdrawal from plantar stimulation; two manifested higher threshold for spasm triggering; two displayed decreased minimum voluntary motor control; and significantly reduced Ashworth and reflex scores (p = 0.001). One patient had no change in any parameter tested, five had decreased reflex motor activity and four had a decrease stretch response. Two catheter complications requiring surgical intervention occurred. There were no IIP malfunctions. The daily dosage of baclofen gradually increased over the observation period in all patients. The initial mean dosage was 164 micro-g/d (+/-134) and rose to 536 micro-g/d (+/-269) at 2 years, although by then only three patients remained.

Ochs et al(74). reported on a multicenter series of 28 patients with chronic spasticity unresponsive to oral baclofen (10 with trauma, 12 with multiple sclerosis, 6 with mixed myelopathies), who were treated with intrathecal baclofen. Muscle tone, reflexes, and systemic drug use were evaluated. Other subjective measures were patient assessment of pain relief, improvement in mobility, facilitation of nursing care, and changes in physical therapy. The results demonstrated that baclofen was difficult to titrate in those patients able to walk by using residual extensor tone. Muscle tone was reduced (Ashworth scale: 3.6 +/-0.35 to 1.75 +/-0.31) and the mean number of spasms per hour decreased from 2.5 to 1.4 after 1 month of intrathecal baclofen administration. The mean drug requirement necessary to maintain the initial effective response was 144 micro-g/d (range 32-620 micro-g) which increased to 203 micro-g/d at the end of the study. Mean followup was 9.5 months (range 1-25). Pain secondary to muscle spasm was effectively controlled, but deafferentation pain remained unaffected in this group of patients. One pump failure and a pump pocket infection occurred, both requiring explantation and reimplantation of new pumps. Four catheters were replaced owing the displacement, blockage, or nerve-root irritation.

Parke et al(75). reported on eight patients (four with multiple sclerosis and four with spinal cord injury) followed for at least 6 months (range not reported) for functional and sleep status after intrathecal baclofen by IIP. These patients were part of Penn's larger series. All had immediate improvement in spasticity and night spasms, while bowel and bladder performance improved in all but one. Among the four patients not independently performing bladder care, one achieved some degree of independence at 3 months, another at 6 months, and the two remaining ones, although not functioning independently, achieved some improvement. Of seven patients needing help from others in dressing, five achieved some level of independence.

The baclofen studies reviewed demonstrated that patients successfully treated with trail bolus doses of intrathecal baclofen are able to maintain this initial effectiveness with increasing daily baclofen dosages. Most studies demonstrated the need for slow, incremental increases in dosage over the first 6 months to 1 year of treatment. Patients who developed tolerance were either successfully treated with higher daily dosages or effectively treated with intrathecal opioids for a short period of time, followed by resumption of baclofen.

The severity of the original motor damage is not necessarily predictive of the functional gain in voluntary motor control, if any, that an individual may achieve with intrathecal baclofen administration, particularly if the dose of baclofen used to control the spasticity reduces extensor motor control. (76). Full benefit of intrathecal baclofen on functional improvements, i.e., sleep patterns, bowel and bladder care, feeding and dressing, may not manifest itself for several months or years after the initiation of therapy.(75). Data addressing improvement in the quality of life are few, and do not permit conclusive judgments regarding that parameter. Drug-device complications, particularly in more recent studies, were infrequent.

## Conclusions

Technologies permitting drug self-administration and automated drug delivery outside the hospital have become increasingly more sophisticated, adaptable, and available, with over 300,000 persons annually receiving home infusion therapy.(8). There are over 600 models of EIPs, several types of access ports, and two noninsulin implantable infusion pumps currently on the US market. Multifunction external and implantable programmable devices are available, and complex delivery regimes that alter dosage, concentration, and rate of administration, are possible.

### Continuous hepatic artery infusion

The literature does not support a conclusion that CHAI by implantable infusion pump is a lifesaving or unique therapeutic intervention (other reasonable alternatives exist). Implantable infusion pumps provide another drug management option for treatment in limited circumstances, although the cost-effectiveness of intrahepatic chemotherapy, intrathecal baclofen, and intraspinal opioids remains unanswered.(77,78,79).

The outcomes measured in that CHAI studies have demonstrated that CHAI does not influence survival in patients with hepatic metastases of colorectal carcinoma, although progression of intrahepatic disease was delayed significantly. Survival is inversely proportional to tumor burden at diagnosis. Patients who are surgically staged and undergo curative resection, or who have tumor replacement volumes less than 50 at the time of diagnosis and treatment, have longer survival times than those who are surgically unresectable (multiple metastases) and are treated with adjuvant cytotoxic agents. The morbidity experienced by patients in cytotoxic studies, and the inherent biases in the study designs, cautiously lead us to limited generalizable conclusions about the effectiveness of CHAI by IIP for the treatment of metastases of colorectal cancer. Chemotherapy with CHAI by IIP offers a limited benefit to patients. This benefit must be evaluated in light of the known potential side effects related to both the drug and device, the costs, and patient's life expectancy.

### Morphine and baclofen

A stepwise treatment plan from nonopioid oral analgesics and antispasmodics to opioids, adjuvant therapy and, as a last resort, neuroablative procedures, should be followed when severe pain or spasticity incapacitates the patient. Eligibility criteria for placement of an IIP should include evaluation of prior responses to noninvasive methods of pain management and spasm control, such as oral or subcutaneous opioids, anti-spasmodics, alone or combined with nonsteroidal anti-inflammatory drugs or anticonvulsants (depending on the disease progression and the patient's symptoms). Life expectancy, physical and behavioral abnormalities that may interfere with the patient's ability to assess pain, the patient's support systems and the cost of the delivery system(79,80). need to be reconciled. Actual or imminent spinal compression, obstruction, or anomaly, as well as all potentially reversible causes of pain or spasticity should be ruled out.(18). A preliminary trial of intraspinal opioid(82). or intrathecal baclofen(71). with a temporary epidural or intrathecal catheter should be undertaken before implantation of an access port of infusion pump so that pain relief or reduction in spasticity, side effects, ADL, and patient acceptance can be evaluated. Implantation of a permanent IIP should be attempted only when less invasive steps have been unsuccessful in alleviating pain or spasticity and the patient experiences acceptable relief during the trial phase. And finally, because of the expense of implantation of infusion pumps and the attendant costs, the patient's anticipated life expectancy should be several months from the time of implantation of the infusion delivery

## References

1 Feigenbaum E. External Open-Loop Pump for the Subcutaneous Infusion of Insulin in Diabetics Health Technology Assessment Report 1984 No. 22, Rockville MD:National Center for Health Services Research and Health Care Technology Assessment (Agency for Health Care Policy and Research)
2 Hotta SS, Adams D. Reassessment of External Insulin Infusion Pumps Health Technology Assessment Report 1990 No. 9, Rockville, MD:Agency for Health Care Policy and Research
3 Waxman B. External Infusion Pump for Heparin Health Technology Assessment Report 1983 No. 20, Rockville, MD:National Center for Health Services Research and Health Care Technology Assessment (Agency for Health Care Policy and Research)
4 Carter ED, Waxman D, Broida J. Implantable Chemotherapy Infusion Pump for the Treatment of Liver Cancer Health Technology Assessment Reports 1983 No. 19, Rockville, MD:National Center for Health Services Research and Health Care Technology Assessment (Agency for Health Care Policy and Research)
5 Waxman B. Implantable Pump for Chronic Heparin Therapy Health Technology Assessment Report 1984 No. 2, Rockville, MD:National Center for Health Services Research and Health Care Technology Assessment (Agency for Health Care Policy and Research)
6 AllenAllan D. Making sense of infusion pumps. Nurs Times. 1988;84(35):46-47.
7 West DL. Infusion pumps (memorandum from the Associate Director, Center for Devices and Radiological Health, to the Associate Commissioner for Health Affairs, U.S. Food and Drug Administration) August 1, 1991
8 [no authors listed] U. S. Congress, Office of Technology Assessment, Home Drug Infusion Therapy Under Medicare, OTA-H 509, Washington, DC: U.S. Government Printing Office, May 1992
9 ECRI.[no authors listed]. Evaluation: Ambulatory infusion pumps. Health Dev. 1991;;20(9):324-358.
10 Arcarese JD. Infusion pump issue-decision package (memorandum) U. S. Food and Drug Administration, Center for Devices and Radiological Health, Office of Training and Assistance January 24, 1989
11 Sefton M. Implantable pumps. Crit Rev Biomed Eng. 1987;14(3):201-240. [pmid: 3297487].
12 Buchwald H, Rohde TD. Implantable infusion pumps. Adv Surg. 1984;18:117-221. [pmid: 6440433].
13 Waldman SD. Implantable drug delivery systems: Practical considerations. J Pain Symptom Manage. 5(3):169-174. [pmid: 2366012].
14 Lazorthes Y, Sallerin-Caute B, Verdie JC, Bastide R. Advances in drug delivery systems and applications in neurosurgery. Adv Tech Stand Neurosurg. 1991;18:143-192. [pmid: 1930373].
15 Rheinstein, P. Infusion pumps (memorandum from the Director, Medicine Staff, Office of Health Affairs, U.S. Food and Drug Administration, to the Director, Office of Health Technology Assessment, Agency for Health Care Policy and Research) August 6, 1993
16 Andrews JC, Williams DM, Cho KJ, et al. Unsatisfactory hepatic perfusion after placement of an implanted pump and catheter system: Angiographic correlation. Radiology. 1989;173:779-781. [pmid: 2813786].
17 Silberman AW, Rosenkranz E, Kosakowski C., et al. A complication of the Infusaid (R) pump: Duodenal atony reversed by urecholine. Journal of Surgical Oncology. 1987;36:210-214. [pmid: 2960855].
18 Pozniak MA, Babel SG, Trump DL. Complications of hepatic arterial infusion chemotherapy. Radiographics. 1991;;11:67-79. [pmid: 1825358].
19 Kemeny MM. Continuous hepatic artery infusion (CHAI) as treatment of liver metastases: Are the complications worth it?. Drug Saf. 1991;6(3):159-165. [pmid: 1829612].
20 Decq P, Keravel Y. Drug pump technical description, operative procedure and post-operative management, in Sindou M, Abbot R, Keravel Y (Eds): Neurosurgery for Spasticity: A Multidisciplinary Approach, New York: Springer-Verlag, 1991 pp 97 101
21 Miller BA et al (Eds). Cancer Statistics Review 1973-1989. U. S. Department of Health and Human Services, National Cancer Institute 1992; NIH PublicationNo. 92-2789
22 Kemeny N, Daly J, Reichman B, et al. Intrahepatic or systemic infusion of fluorodeoxyuridine in patients with metastases from colorectal carcinoma: A randomized trial. Ann Intern Med. 1987;107:459-465. [pmid: 2957943].
23 Scheele J, Stangl R, Altendorf-Hofmann, A. Hepatic metastases from corectal carcinoma: Impact of surgical resection on the natural history. Br J Surg. 77:1241-1246. [pmid: 2253003].
24 Pettavel J, Gardiol D, Bergier n, Schnyder P. Fatal liver cirrhosis associated with long-term arterial infusion of floxuridine (letter) Lancet Nov 15, 1986 1162 1163
25 Sugarbaker PH, Gunderson LL, Wittes RE. Colerectal cancer, in Devita VT, Hellman S, Rosenberg SA (Eds): Cancer. (3rd edition), Philadelphia: JB Lippincott, 1985 pp. 795 811
26 Ensminger WD, Rosowsky A, Levin DC, et al. A clinical-pharmacological evaluation of hepatic arterial infusions of 5-fluorouracil. Cancer Res. 1978;38:3784-3792. [pmid: 151583].
27 Erlichman C, Fine S, Wong, Elhakim T. A randomized trial of fluorouracil and folinic acid in patients with metastatic colorectal carcinoma. J Clin Oncol. 1988;6(3):469-475. [pmid: 3280741].
28 Curley SA, Hohn DC, Roh MS. Hepatic artery infusion pumps: Cannulation techniques and other surgical considerations. Langenbecks Arch Chir. 1990;375:119-124. [pmid: 2139485].
29 Ramming KP, O'Toole K. The use of the implantable chemoinfusion pump in the treatment of hepatic metastases of colorectal cancer. Arch Surg. 1986;121:1440-1444. [pmid: 2947551].
30 Wagman, LD, Kemeny MM, Leong L, et al. A prospective, randomized evaluation of the treatment of colorectal cancer metastatic to the liver. J Clin Oncol. 1990;8(11):1885-1893. [pmid: 2146370].
31 Martin JK, O'Connel MJ, Wieand HS, et al. Intra-arterial floxuridine vs. systemic fluorouracil for hepatic metastases from colorectal cancer.A randomized trial. Arch Surg. 1990;125(8):1022-1027. [pmid: 2143063].
32 Lorenz M, Hortenrott Hottenrott C, Inglis R, Krikowa-Reimann M. Prevention of extrahepatic disease during intraarterial floxuridine for colorectal river metastases by simultaneous systemic 5-fluorouracil treatment: A prospective multicenter trial. Gan To Kagaku Ryoho. 1989;16(12):3662-3671. [pmid: 2531992].
33 Kemeny N, Daly J, Reichman B, et al. Intrahepatic or systemic infusion of fluorodeoxyuridine in patients with metastases from colorectal carcinoma: A randomized trial. Ann Intern Med. 1987;;107:459-465. [pmid: 2957943].
34 Hohn DC, Stagg RJ, Friedman MA, et al. A randomized trial of continuous intravenous versus hepatic intra-arterial floxuridine in patients with colorectal cancer metastatic to the liver. The Northern California Oncology Group trial. J Clin Oncol. 1989;7(11):1646-1654. [pmid: 2530317].
35 Safi F, Schumacher K, Roscher R, et al. Regional chemotherapy in liver metastases of colorectal carcinoma: Monitoring with arterial computed tomography. Cancer Invest. 1990;8(2):123-134. [pmid: 2144783].
36 Civalleri D, Cafiero F, Cosimelli C, et al. Regional arterial chemotherapy of liver tumors tumours. I. Performance comparison between a totally implantable pump and a conventional access system. Eur J Surg Oncol. 1986;12:277-282. [pmid: 3758367].
37 Tuchmann A, Schiller J, Kroiss A, Dinst K. Hepatic artery infusion chemotherapy. HPB Surg. 1990;;2:21-28. [pmid: 2149279].
38 Ferguson, J. External and Implantable Infusion Pumps (memorandum from the Director, Office of Medical Applications of Research National Institutes of Health, to the Director, Office of Health Technology Assessment, Agency for Health Care Policy and Research August, 1993
39 Andrews JC, Kuntsen C, Terio P, et al. Hepatobiliary toxicity of 5-fluoro-2'-deoxyuridine: Intra-arterial versus portal venous routes of infusion. Invest Radiol. 1991;26:461-464. [pmid: 1829068].
40 Atiq OT, Kemeny N, Niedzweicki D, Botet J. Treatment of unresectable primary liver cancer with intrahepatic fluorodeoxyridine and mitomycin C through an implantable pump. Cancer. 1992;69:920-924. [pmid: 1370918].
41 Andrews JC, Williams DM, Cho KJ, et al. Unsatisfactory hepatic perfusion after placement of an implanted pump and catheter system: Angiographic correlation. Radiology. 1989;173:779-781. [pmid: 2813786].
42 Coombs, D. Intraspinal analgesic infusion by implanted pump. Ann NY Acad Sci. 1988;531:108-122. [pmid: 2837974].
43 Ready LB. Regional analgesia with intraspinal opioids, in Bonica J (Ed). The management of pain, Philadelphia: Lea and Fibiger, 1990 1968 1969
44 Zylicz Z, Twycross RG. Oral opioids and the treatment of cancer pain. Neth J Med. 1991;39:108-114. [pmid: 1660107].
45 Lipp J. Possible mechanisms of morphine analgesia. Clin Neuropharmacol. 1991;14:131-147. [pmid: 1849794].
46 Crul BP, Delhaas D. Technical complications during long-term subarachnoid or epidural administration of morphine in terminally ill cancer patients: A review of 140 cases. Reg Anesth. 1991;16:209-213. [pmid: 1911496].
47 Waldman SD. The role of spinal opioids in the management of cancer pain. J Pain Symptom Manage. 1990;5(3):163-168. [pmid: 2366011].
48 Nitescu P, Appelgren L, Linder LE, et al. SpiduralEpidural versus intrathecal morphine-bupivacaine: assessment of consecutive treatments in advanced cancer pain. J Pain Symptom Manage. 1990;5:18-26. [pmid: 2324557].
49 Ventafridda V, Spoldi E, Caraceni A, DeConno F. Intraspinal morphine for cancer pain. Acta Anaesthesiol Scand. suppl 85. 1987;31:47-53.
50 Hassenbusch SJ, Pillay PK, Magdinec M, et al. Constant infusion of morphine for intractable cancer pain using an implanted pump. J Neurosurg. 1990;;73:405-409. [pmid: 2384779].
51 Onofrio BM, Yaksh TL. Long-term pain relief produced by intrathecal morphine infusion in 53 patients. J Neurosurg. 1990;72:200-209. [pmid: 1688618].
52 Penn RD, Paice JA. Chronic intrathecal morphine for intractable pain. J Neurosurg. 1987;67:182-186. [pmid: 3598678].
53 Madrid JL, Fatela LV, Alcorta J, et al. Intermittent intrathecal morphine by means of an implantable reservoir: A survey of 100 cases. J Pain Symptom Manage. 1988;3(2):67-71. [pmid: 3356916].
54 Gourlay GK, Plummer JL, Cherry DA, et al. Comparison of intermittent bolus with continuous infusion of epidural morphine in the treatment of severe cancer pain. Pain. 1991;47:135-140. [pmid: 1762806].
55 Auld AW, Maki-Jokela A, Murdough M. Intraspinal narcotic analgesia in the treatment of chronic pain. Spine. 1985;10(8):777-781. [pmid: 3841231].
56 Coombs DW, Saunders RL, Gaylor MS, et al. Relief of continuous chronic pain by intraspinal narcotics infusion via an implanted reservoir. JAMA. 1983;250(17):2336-2339. [pmid: 6688832].
57 Hogan Q. Haddox JD, Abram S, et al. Epidural opiates and local anesthetics for the management of cancer pain. Pain. 1991;46(3):271-279. [pmid: 1758711].
58 Foley K. The treatment of cancer pain. N Engl J Med. 1985;313(2):84-95. [pmid: 2582259].
59 Portenoy RK. Chronic opioid therapy in nonmalignant pain. J Pain Symptom Manage. 1990;5(1):546-62.
60 Arner S, Meyerson BA. Lack of analgesic effect of opioids on neuropathic and idiopathic forms of pain. Pain. 1988;33:11-23. [pmid: 2454440].
61 American Pain Society. Principles of Analgesic Use in the Treatment of Acute Pain and Chronic Cancer Pain: A Consise Guide to Medical Practice, Washington, DC 1989
62 Bonica J, Ventafridda V, Twycross RG. Cancer Pain; in Bonica J (Ed): The Management of Pain, Philadelphia: Lea and Febiger, 1990 400 460
63 Bonica JJ, Ekstrom JL. Systematic opioids for the management of cancer pain: An updated review, in Benedetti C, Chapman CR, Giron G (Eds): Advantages in Pain Research and Therapy: Opioid Analgesia, Recent Advances in Systemic Administration, New York: Raven Press, 1990 pp. 434 435
64 Adams RD, Victor M. (Eds). Principles of Neurology. 4th ed, New York: McGraw-Hill Information Services Company, 1989
65 Maynard FM, Karunas RS, Waring WP. Epidemiology of Spasticity following traumatic spinal cord injury. Arch. Phys Med. Rehab. 1990;71:566-589.
66 Boisson D, Eyssette M. Medical treatment of spasticity, in Sindou M, Keravel Y. (Eds): Neurosurgery for Spasticity: A Multidisciplinary Approach, New York: Sringer-Verlag, 1991
67 Gybels J, Van Roost D. Spinal cord spasticity, in Sindou M, Keravel Y (Eds): Neurosurgery for Spasticity: A Multidisciplinary Approach, New York: Springer-Verlag, 1991 pp. 73 81
68 Siegfried J. Deep Brain and Cerebeller Stimulation for Spasticity, in Sindou M, Keravel Y. (Eds): Neurosurgery for Spasticity: A Multidisciplinary Approach, New York: Springer-Verlag, 1991 pp. 83 87
69 Mertens P, Sindou M. Selective peripheral neurotomies for the treatment of spasticity in Sindou M, Keravel Y. (Eds). Neurosurgery for Spasticity: A Multidisciplinary Approach, New York: Springer-Verlag, 1991 pp. 119 132
70 Sindou M, Abdenneh N, Abdennebi B, Sharkey P. Microsurgical selective procedures in peripheral nerves and the posterior root-spinal cord junction for spasticity. Appl. Neurophysiol. 1985;48:97-104. [pmid: 3837653].
71 Penn, RD. Intrathecal baclofen for spasticity of spinal cord: Seven years of experience. J Neurosurg. 1992;77:236-240. [pmid: 1625011].
72 Lazorthes Y, Sallerin-CuateCaute B, Verdie JC, et. at. Chronic intracthecal intrathecal baclofen administration for control of severe spasticity. J Neurosurg. 1990;72:393-402. [pmid: 2303874].
73 Loubser PG, Narayan RK, Sandin KJ, et al. Continuous infusion of intrathecal baclofen: Long-term effects on spasticity in spinal cord. Paraplegia. 1991;29:48-64. [pmid: 2023770].
74 Ochs B, Struppler A, Meyerson BA. Intrathecal baclofen for long-term treatment of spasticity: A multi-care study. N Neurosurg Psychiat. 1989;52:933-939.
75 Parke B, Penn RD, Savoy SM, Corcos D. Functional outcome after delivery of intrathecal baclofen. Arch Phys. Med. Rehab. 1989;70:30-32.
76 Latash ML, Penn Rd, Corcos DM, Gottlieb GL. Effects of intrathecal baclofen on voluntary motor control in spactic paresis. J Neurosurg. 1990;72:388-392. [pmid: 2303873].
77 Vogelzang NJ, Raune MJ, Dhowlatshahi K, Chodak GW. A programmable and implantable pumping system for systemic chemotherapy: A performance analysis in 52 patients. J Clin Oncol. 1987;5:1968-1976. [pmid: 3316517].
78 Lanning RM, Hrushesky WJ. Outpatient time-specified infusion of fluoropyrimidines by implanted pump is less costly than flat delivery by external pump. Progress in Clinical Research. 1990;341(B):397-409.
79 Bedder MD, Burchiel K, Larson A. Cost analysis of two implantable narcotic delivery systems. J Pain Symptom Manage. 1991;6(6):368-373. [pmid: 1908884].
80 Waldman SD, Coombs DW. Selection of Implantable narcotic delivery systems. Anesth Analg. 1989;68(3):377-384. [pmid: 2919777].
81 Fedders Fedder S. Intrathecal administration of morphine for pain of malignant origin. Surg Gyn Obstet. 1990;170:273-275.
82 Waldman SD, Feldstein GS, Allen ML, Turnage G. Selection of patients for implantable narcotic delivery systems. Anesth Analg. 1986:883-885.