# Signal-Averaged Electrocardiography

Health Technology Assessment, Number 11

## Abstract

Signal-averaged electrocardiography (SAECG) is a technique involving computerized analysis of segments of a standard surface electrocardiogram. It is used for detecting small electrical impulses, termed ventricular late potentials, that follow the QRS segment. They are embedded in the electrocardiogram but ordinarily obscured by skeletal muscle activity and other extraneous sources of "noise" encountered in recording a standard electrocardiogram. Ventricular late potentials in patients with cardiac abnormalities, especially coronary artery disease or following an acute myocardial infarction, are associated with an increased risk of ventricular tachyarrhythmias and sudden cardiac death. Proponents of SAECG claim that it can obviate the need for invasive techniques commonly used to identify high-risk patients for interventions that treat or prevent ventricular tachyarrhythmia and sudden death.

No randomized clinical trials evaluating SAECG have been completed; data from an ongoing National Institutes of Health-sponsored clinical trial are expected to be available in 3-4 years. The current data on SAECG show relatively consistent high negative predictive values, poor positive predictive values, and variable sensitivity and specificity when the technique is used on patients with cardiomyopathy or following a myocardial infarction. The available evidence also indicates that combining SAECG with other tests of cardiac function is superior to using any single test for risk. The utility of SAECG alone as an indicator of risk remains to be proven. SAECG combined with other standard tests of risk has been demonstrated to have clinical utility in patients following an acute myocardial infarction. Other patient populations have not been conclusively shown to benefit from its use.

## Foreword

The Center for Practice and Technology Assessment (CPTA) evaluates the risks, benefits, and clinical effectiveness of new or established medical technologies. In most instances, assessments address technologies that are being reviewed for purposes of coverage by federally funded health programs.

The CPTA assessment process includes a comprehensive review of the medical literature and emphasizes broad and open participation from within and outside the Federal Government. A range of expert advice is obtained by widely publicizing the plans for conducting the assessment through publication of an announcement in the Federal Register and solicitation of input from Federal agencies, medical specialty societies, insurers, and manufacturers. The involvement of these experts helps ensure inclusion of the experienced and varying viewpoints needed to round out the data derived from individual scientific studies in the medical literature.

The CPTA staff analyzed and synthesized data and information received from experts and the scientific literature. The results are reported in this assessment. Each assessment represents a detailed analysis of the risks, clinical effectiveness, and uses of new or unestablished medical technologies. If an assessment has been prepared to form the basis for a coverage decision by a federally financed health care program, it serves as the Public Health Service's recommendation to that program and is disseminated widely.

The CPTA is one component of the Agency for Health Care Policy and Research (AHCPR), Public Health Service, Department of Health and Human Services.

Douglas B. Kamerow, M.D., M.P.H., Director, Center for Practice and Technology Assessment John M. Eisenberg, M.D., Administrator, Agency for Health Care Policy and Research

- Questions regarding this assessment should be directed to:
- Center for Practice and Technology Assessment
- Agency for Health Care Policy and Research
- 6010 Executive Boulevard, Room 316
- Rockville, MD 20852
- Telephone: (301) 594-4026

## Abbreviations

Acc:: Accuracy

ART:: Arrhythmia research technology

BBB:: Bundle branch block

CAD:: Coronary artery disease

CAST:: Cardiac arrhythmia suppression trials

CFR:: Case fatality rate

CHF:: Congestive heart failure

CI:: Confidence interval

dQRS:: Duration of the filtered QRS complex >106 ms

ECG:: Electrocardiogram

FD:: Frequency domain

FDA:: Food and Drug Administration

HCFA:: Health Care Financing Administration

IDC:: Idiopathic dilated cardiomyopathy

LAS:: Low amplitude signal

LVEF:: Left ventricular ejection fraction

LVH:: Left ventricular hypertrophy

MeSH:: Medical subject heading

MI:: Myocardial infarction

MUGA:: Multigated acquisition

NPV:: Negative predictive value

NS:: Not stated

NSR:: Normal sinus rhythm

NYHA:: New York Heart Association

PES:: Programmed electrical stimulation

PPV:: Positive predictive value

RMS:: Root mean square voltage during the last 40 ms of the QRS complex <25 µV

RNV:: Radionuclide ventriculography

SAECG:: Signal-averaged electrocardiography

SD:: Sudden death

1SD:: One standard deviation

Se:: Sensitivity

Sp:: Specificity

STA:: Spectral turbulence analysis

TD:: Time domain

VAT:: Ventricular activation time

VF:: Ventricular fibrillation

VLP:: Ventricular late potentials

VT:: Ventricular tachyarrhythmia

## Introduction

The Center for Practice and Technology Assessment, Agency for Health Care Policy and Research, conducted this technology assessment of the safety, effectiveness, and clinical utility of signal-averaged electrocardiography (SAECG) at the request of the Health Care Financing Administration. Biomedical signal-averaging techniques have been used in neuroscience to study cortical sensory-evoked potentials, in obstetrics to separate fetal and maternal electrocardiograms, and in cardiology to detect ventricular late potentials (VLPs), primarily in patients with ischemic heart disease.(1, 2) During the past 2 decades, proponents have attempted to find a reliable use for SAECG in evaluating patients with sustained or nonsustained ventricular tachyarrhythmia after myocardial infarction (MI), nonneurogenic syncope, and cardiomyopathy.(3, 4) Other proposed uses of SAECG include monitoring heart transplant rejection and antiarrhythmic drug therapy. This assessment evaluates the ability of SAECG to predict sudden death or ventricular tachyarrhythmia in the presence of VLP.

## Methods

A literature search was performed using the online electronic retrieval systems PaperChase and MEDLINE, with the following keywords or medical subject heading (MeSH) terms: VLPs and electrocardiography (ECG), and spectral analysis (limited by signal averaging). Approximately 500 articles, published in the English language between 1985 and September 1996, were retrieved. Citations were added from reference lists of appropriate articles and textbooks. Greater weight was given to data from prospective studies in which a control or reference group was compared with the study population.

## Background

Approximately 1.5 million Americans suffer myocardial infarctions each year.(5) Of these, approximately one half are hospitalized, and one third die before reaching the hospital.(4-6) Of those who reach the hospital, 85 percent experience residual ventricular irritability(7-9) in the form of primary ventricular fibrillation (4-8 percent),(10) ventricular tachyarrhythmia (6-10 percent),(11) or sudden death (5 percent).(12) Only 10 percent of all hospitalized acute MI patients undergo full electrophysiologic testing (20 percent of whom receive automatic implantable cardioverter defibrillators).(13) Although the case fatality rate for ischemic heart disease has declined by 50 percent over the past 30 years (partially attributed to coronary intensive care units and early thrombolytic and antiarrhythmic drug interventions), 50-60 percent of patients with ischemic heart disease die suddenly.(14) The case fatality rate for patients hospitalized with acute MI, complicated by congestive heart failure or primary ventricular fibrillation, is 48 percent, vs. 1.5 percent in uncomplicated acute MI patients (p = 0.001).(10) Over the past 15 years, the incidence of primary ventricular fibrillation during an acute MI has remained unchanged (4-8 percent/year). Risk factors associated with repeat infarct or sudden death are recurrent myocardial ischemia, moderate to severe reduction in the left ventricular ejection fraction, and spontaneous ventricular ectopy (>10/hour).(15, 16) The risk factors for ventricular tachyarrhythmia are age, congestive heart failure complicating an acute MI, and prior MI.(9, 17) The 1-year case fatality rate for patients with a second MI or sustained chronic angina is twice that of persons with an initial acute MI.

Sudden cardiac death results from malignant tachyarrhythmias (ventricular tachycardia or fibrillation).(18) Most patients who die suddenly from cardiac causes have underlying severe coronary artery disease, infiltrative or hypertrophic cardiomyopathies, or primary electrical disturbances of the cardiac conduction system.(19) A cardiac etiology, e.g., sinus node disease, ventricular tachyarrhythmia, supraventricular tachycardia, heart block, or syncopal episodes, can be verified in only a small proportion of patients (mean 14 percent); the etiologies of most cases remain undetermined.(3)

The two principal mechanisms responsible for ventricular tachyarrhythmia are reentry and enhanced automaticity.(14) Spontaneous, sustained ventricular tachyarrhythmia is thought to originate from the reentry of aberrant, asynchronous electrical impulses in the <25 µV range, called ventricular late potentials, caused by reduced conduction velocity and/or elongated inhomogeneous conduction pathways.(1, 20, 21) Ventricular late potentials are generated from viable isolated cardiac muscle bundles bordering an infarction or ischemic zone of the myocardium and are propagated through a zone of slow conduction (arrhythmogenic substrate) to a zone of healthier myocardium where repolarization has already begun. Enhanced automaticity leads to repetitive firing from a single focus within the heart and may be precipitated by hypoxia, ischemia, acid-base disturbances, and drugs. Late potentials are believed to be precursors of sudden death, ventricular tachyarrhythmia, and/or ventricular fibrillation.(20)

Ventricular late potentials were first described in the late 19th century and consist of small electrical impulses (1-2 µV) that are embedded within the electrocardiographic junction between the electrocardiograph wave complex or interval complex and ST segment (QRS-ST) of an ECG.(21) They are obscured by skeletal muscle activity and other extraneous sources of noise within the 5- to 20-µV range.

In natural history studies of at-risk populations, the prevalence of VLP is higher in patients with a history of coronary artery disease and MI (21-43 percent), spontaneous and induced sustained ventricular arrhythmias (primarily ventricular tachycardia and ventricular fibrillation), and left ventricular aneurysms than in patients with normal ventricular function.(22, 23) Ventricular late potentials rarely occur without myocardial disease (0-6 percent of studied control populations).(1, 24)

Signal-averaging techniques, which reduce the noise (low-frequency, high-amplitude signals) interfering with the surface ECG, have been used since the 1970s to detect VLP.(24-26) A positive SAECG is one in which VLP is detected. The SAECG procedure involves recording the-surface ECG during a period of normal sinus rhythm, followed by amplification of the entire ECG (10^3^ - 10^8^ x the original signal), which exaggerates all electrical signals. The principal noise removed by signal averaging is from skeletal muscle. Once amplified, the voltage signal from each lead undergoes analog to digital conversion at frequent fixed time intervals. A computer signal-averages the signal from each lead against the midpoint of the R wave or the peak slope in front of the QRS waves in the normal sinus rhythm template, previously chosen by the operator or assigned by the software. More than 400 beats are recommended for averaging, although in older systems averages were calculated with fewer than 250 beats. An abnormal tracing from a patient with spontaneous sustained ventricular tachycardia shows low-amplitude signal in the terminal QRS complex, which extends 210 ms after QRS onset. Mean voltage (V40) is in the terminal 40 ms of the QRS.

Currently, there are two methods of body-surface ECG signal-averaging: time-domain (or ensemble averaging or high pass filtering) and frequency-domain (or spatial or spectral averaging). Time-domain averaging is a computer-driven sequential digital process based on the vector analysis of three orthogonal ECG leads (X, Y, and Z) that separates and extracts high-frequency late potentials from lower frequency ST segments by the use of directional filters, enabling filter output to correspond in time to signal input. Most of the noise is eliminated by electrically isolated amplifiers, shielded lead systems, and filters to reduce aberrant noise to <1 µV.

Conventional time domain analyses have limitations that to some degree can be mitigated by other more detailed analyses, including frequency domain analyses.(27, 28) This involves further filtering of overlapping QRS segments, subjecting them to fast-Fourier transformation, and plotting the analysis in a three-dimensional representation.

No consensus exists on the definition of VLP in time-domain or frequency-domain analysis.(24, 28) Investigators have used increases in spectral amplitude >30 dB) at frequencies between 40 and 200 Hz and prolonged ventricular activation times to show an abnormal frequency domain. Time-domain parameters (root mean square voltage during the last 40 ms of the QRS complex <25 µV [RMS40], duration of low-amplitude signals during the last 40 ms >38 ms [LAS40], or duration of the filtered QRS complex >106 ms [dQRS]) are used to mark the presence of VLP in the SAECG.(30) Ventricular late potentials are defined relative to the beginning and endpoints of the filtered QRS, which are directly influenced by residual noise in the system after data acquisition and the average number of beats. Therefore, many opportunities exist for misclassification among the different SAECG systems.(31)

Age, gender, thrombolytic therapy, antiarrhythmic drug use,(32, 33) timing of the SAECG in the postinfarction period,(34) and the period from diagnosis of ventricular tachyarrhythmia to SAECG testing(35) are nonsystem factors that may influence the incidence of the VLP. McGuire et al(36) found no difference in age, gender, site of infarct or thrombolytic therapy in SAECG-positive or SAECG-negative patients. Malik(37) confirmed that there was no difference in the incidence of positive SAECG in patients receiving thrombolytic therapy. A more recent paper, however, concluded that SAECG was abnormal more often when thrombolytic therapy was omitted.(38)

There are recording difficulties in both time-domain and frequency-domain systems. Time-domain is neither suitable for patients with QRS complexes >120 ms nor able to detect changes in late potential activity. Frequency domain shows significant beat-to-beat variability in morphology, duration, and latency. The ability to detect this variability, however, remains investigational. Some investigators believe that these problems underlie the biologic variation of the myocardium (tachyarrhythmias, myocardial oxygen uptake) or the influence of drugs during ischemia rather than poor reproducibility of the method.(29)

In 1991, the American Heart Association, European Heart Association, and American College of Cardiology Task Force Committee on SAECG noted in a joint scientific statement that although commercially available SAECG devices had different technical systems, algorithms, and recording units, and a definition of a positive SAECG could not be agreed on, standards should be established for data acquisition and analysis, and the role of SAECG in clinical decisionmaking should be defined.(1) At that time, no consensus had been reached on technical design considerations because of ongoing component development. No particular method of data analysis was endorsed. The committee pointed out that multivariate analysis showed an independent effect of a positive SAECG from other risk markers such as reduced left ventricular ejection fraction or the presence of sustained ventricular tachyarrhythmias within 1 year of an acute MI. Earlier investigations showed a positive correlation between VLP and inducibility of ventricular tachyarrhythmia during electrophysiologic testing.(39) Proponents of noninvasive SAECG believed it could stratify patients thought to be at risk for sudden death or ventricular tachyarrhythmia after acute MI without invasive procedures such as coronary angiography or programmed electrical stimulation, particularly in light of its high negative predictive value. However, as the committee noted, "the relatively low positive predictive value of SAECG in post-MI patients emphasizes the need for continued methodological refinements that will increase its diagnostic power."(1)

Since 1991, little standardization of SAECG components has taken place. A multicentered clinical trial sponsored by the National Heart, Lung, and Blood Institute is underway as a spinoff of the cardiac arrhythmia suppression trials (CAST) to help evaluate the role of SAECG in the diagnosis of ischemic heart disease. The results of this trial should be available in 3-4 years.

In January 1996, the American College of Cardiology published an expert consensus document on SAECG with the following findings:(40)

Established value of SAECG:

- Stratification of risk of developing sustained ventricular arrhythmias in patients recovering from MI who are in sinus rhythm without electrocardiographic evidence of bundle branch block (BBB) or intraventricular conduction delay (QRS complex >120 ms).
- Identification of patients with ischemic heart disease and unexplained syncope who are likely to have inducible sustained ventricular tachycardia.

Valuable in clinical care, further supportive evidence desirable:

- Stratification of risk of developing sustained ventricular arrhythmias in patients with nonischemic cardiomyopathy.
- Assessment of success of operation for sustained ventricular tachycardia.

Promising but currently unproved:

- Detection of acute rejection of heart transplants.
- Assessment of efficacy or proarrhythmic effects of antiarrhythmic drug therapy in patients with ventricular arrhythmias.
- Assessment of success of pharmacologic, mechanical, or surgical interventions to restore coronary artery blood flow.

Not indicated:

- Patients with ischemic heart disease and documented sustained ventricular arrhythmias.
- Stratification of risk of developing sustained ventricular arrhythmias in asymptomatic patients without detectable heart disease.

Approximately 17 SAECG devices, marketed by 12 manufacturers, are now available. All devices have different design components and different signal-processing algorithms and operator-selectable variables (Table 1).

Table 1. Signal-averaged electrocardiographic devices approved for marketing in the United States (1995)

Manufacturer | Model No.
Mortara Instrument | 101 HiRes
Marquette Electronics | MAC I-302 MAC 12 Hi-Res
Arrhythmia Research Technology | 1200 EPX
Aerotel | Hi-PEC
Nicolet Instrumentation | MED-80
Fidelity Medical | LP-3 LP 3000 LP Plus
Corozonix | Predictor Predictor II Predictor IIc
Del Mar Avionics | Micropotential Analyzer 705A
Wex Medical Instrumentation | Multidomain Cardiac System HD-3L
Diagnostic Medical Instruments | Altair Hi-Res Recorder
Hewlett Packard | M1754A

Published clinical data were reviewed to determine the evidence base for using SAECG in high-risk subpopulations. The literature, published within the past 5 years, has focused on the prognostic ability of SAECG in acute MI and cardiomyopathy, sensitivity analyses of SAECG components such as filters, and other spectral applications of time-domain data. The clinical data in this assessment address acute MI and cardiomyopathy, although the range of published studies addresses SAECG in the diagnosis of syncope, heart rejection, and antiarrhythmic drug efficacy.

### Acute Myocardial Infarction

Patients who survive an acute MI represent the largest population to which an SAECG could be clinically applied. Table 2 alphabetically lists representative clinical studies conducted from 1986 through 1996 which document the ability of SAECG to predict sudden death or ventricular tachyarrhythmia in postacute MI patients.

Table 2. Case series published from 1985-1996 that measured the ability of signal-averaged electrocardiography to predict sudden death or ventricular tachyarrhythmias after acute myocardial infarction

Preference | No. of patients | Device | Parameters defining VLP dQRS^a^ RMS40^b^ LAS40^c^ | | | Definition of +SAECG | Se (%) | Sp (%) | +PV (%) | -PV (%) | Mean followup days (range) | End-points^d^ (%) | No. +SAECG (%) during followup
Ahuja(41) | 262 | ART 1200 EPX | | + | | RMS40 | NS | NS | .15 | .98 | 315±74 | 17/262 (7) | 36/262 (14)
Breithardt(20) | 132 | Princeton signal average No. 4202 | | | + | LAS40 | .66 | .60 | .23 | .90 | 450±330 | 9/132 (7) | 59/132 (45)
Brembilla-Perrot(42) | 328 | LP 3000 (Cardionics) | + | | + | Any 1 parameter | NS | NS | NS | NS | 1,034±794 | 16/328 (5) | 151/328 (46)
Cripps(43) | 176 | ART 101 | + | + | + | Any 1 parameter | .82 | .81 | .22 | .99 | 450±210 (90-720) | 11/176 (6) | 41/176 (23)
de Chillou(44) | 114 | MAC 12/15 | + | + | + | Any 2 parameters | NS | NS | NS | NS | 330±90 (180-540) | 25/114 (22) | 26/114 (23)
Denes(45) | 787 | ART 1200 or Corozonix Predictor | + | + | + | dQRS | NS | NS | NS | NS | 300±90 | 92/787 (12) | 97/787 (12)
Denniss(46) | 306 | DEC 11/34 computer (Fortran (program) | + | | | dQRS | .66 | .78 | .24 | .96 | 360 | 43/306 (14) | 80/306 (26)
Do(47) | 90 | Corozonix Predictor | + | + | + | All 3 parameters | 1.0 | .78 | .16 | 1.0 | NS | NS | 26/90 (29)
El-Sherif(34) | 156 | ART 1200 EPX | + | + | | dQRS, or RMS40 | .35 | .79 | .38 | .76 | (0-365) | 20/156 (13) | 81/156 (52)
El Sherif(48) | 1,158 | ART 1200 EXP or Corozonix Predictor | + | + | + | dQRS, or RMS40 | .48 | .90 | .17 | .98 | 310±96 (0-365) | 45/114 (40) | 139/158 (12)
Farrell(49) | 416 | ART 1200 EPX | + | + | + | Any 2 parameters | .63 | .81 | .17 | .81 | 612 (1-1,112) | 47/416 (11) | 89/418 (21)
Gomes(50) | 115 | ART 101 | + | + | + | Any 1 parameter | .63 | .84 | .38 | .93 | 420±240 | 16/115 (14) | 51/115 (44)
Gomes(51) | 102 | ART 101 | + | + | + | Any 1 parameter | .75 | .60 | .24 | .94 | 360±180 | 15/102 (15) | 30/102 (29)
Hohnloser(52) | 173 | NS | + | + | + | Any 2 parameters | .56 | .78 | .12 | .97 | 360±150 | 9/173 (5) | 41/173 (24)
Kuchar(53) | 210 | ART | + | | + | LAS40 or dQRS | NS | .65 | .17 | NS | 220 (median) (180-720) | 15/210 (7) | 78/210 (37)
Mäkijärvi(54) | 130 | Hewlett Packard HP1000 | + | + | + | Variable | .81 | .79 | .44 | .95 | 720 | NS | NS
Malik(55) | 553 | ART 1200 EPX | + | + | + | Any 2 parameters | .58 | .72 | .09 | NS | 360 | 50/553 (9) | 50/553 (9)
McClements(56) | 301 | Corozonix Predictor | + | + | + | Any 1 parameter | .64 | .80 | .11 | .98 | 367 | 13/301 (4) | 123/301 (4)
McGuire(36) | 50 | ART 101 | + | + | | dQRS or RMS40 | .80 | .47 | .27 | .90 | 10 | 10/50 (20) | 29/50 (58)
Mercando(57) | 121 | ART 1200 EPX | + | + | + | Any 2 parameters | .52 | .68 | .32 | .83 | 870±420 | 48/121 (40) | 26/121 (21)
Pedretti(58) | 303 | Fidelity Medical LP 3000 | + | + | + | Any 2 parameters | .79 | .75 | .17 | .98 | 450±210 | 19/303 (6) | 77/303 (25)
Reinhardt(59) | 769 | NS | + | | | dQRS | .76 | .63 | .10 | .98 | 180 | 33/778 (4) | 266/778 (29)
Richards(60) | 225 | DEC 11/34 | + | | | dQRS | .55 | .82 | .17 | .97 | 740 (median) | 34/225 (15) | NS
Rodriguez(61) | 190 | NS | + | | + | dQRS | .39 | .91 | .48 | .88 | 750 | 33/190 (17) | 23/178 (12)
Steinberg(62) | 182 | Corozonix Predictor | + | + | + | Any 1 parameter | .69 | .64 | .15 | .95 | 420±210 (30-960) | 38/182 (21) | 71/182 (39)
Turitto(27) | 90 | ART 101 PCD | + | + | | dQRS or RMS40 | .75 | .78 | .14 | .98 | 0-5 | 1 (1) | 12/89 (13)
Verzoni(63) | 220 | ART 101 | + | + | + | Any 2 parameters | .83 | .73 | .08 | .99 | 360 (45-360) | 62/220 (28) | 46/192 (24)
Zimmerman(64) | 223 | Siemens Mingograph 82 | + | | + | LAS40 +dQRS | .67 | .80 | .16 | .98 | 450±135 | 17/223 (8) | 45/223 (20)

a Duration of the filtered QRS complex > 106 ms.

b Root mean square voltage during the last 40 ms of the QRS complex <25 µV.

c Duration of low-amplitude signals during the last 40 ms >38 ms.

d SD, VT, or MI.

Abbreviations: ART = arrhythmia research technology; NS = not stated; +PV = positive predictive value; -PV = negative predictive value; Se = sensitivity; Sp = specificity; SD = sudden death; VT = ventricular tachycardia; MI = myocardial infarction.

Ahuja et al(41) prospectively studied 262 patients with an acute MI. During the following 10.5 ± 2.4 months, 36 patients (14 percent) had a positive SAECG and 17 patients (7 percent) had arrhythmic events. The best predictive results were seen in patients with an anterior MI.

Breithardt et al,(20) in an early prospective study designed to identify patients at risk for ventricular tachyarrhythmias, found VLPs in 45 percent of patients. They pooled these data with results from seven earlier prospective studies (2,039 patients) showing either acute MI or chronic coronary artery disease and found that VLPs were present in 13.9 percent of patients with coronary artery disease who were followed for 20 ± 5 months and in 4-40 percent of patients with acute MI followed for 39 ± 15 months. In patients with and without VLP, sudden death (<1 hour after MI) occurred in 3.6-21 percent and 0.9-4 percent of patients; death from cardiac causes was 7-40 percent and 0-5 percent, respectively; and the occurrence of ventricular tachyarrhythmia was 2-29 percent and 1-5 percent, respectively.

Brembilla-Perrot et al(42) performed SAECG on 328 patients without bundle branch block. During the relatively long followup period of 3.7 ± 2.2 years, 46 percent of patients had a positive SAECG, but only 5 percent died suddenly or suffered from ventricular tachyarrhythmia.

Cripps et al(43) prospectively studied 176 patients 7 days post-MI. Multiple regression analyses of seven variables indicated exercise testing as the only independent variable reliably predicting ischemic events. However, SAECG did provide prognostic information concerning arrhythmic events (sensitivity 82 percent).

De Chillou et al(44) prospectively studied 114 patients post-MI with SAECG performed within 48 hours of infarct (early) and again 6-18 months (late) after hospital discharge. Results indicated that a change from an early normal to a late abnormal SAECG was highly indicative of recurrent ischemic events.

Denes et al(45) prospectively studied SAECG after thrombolytic therapy and/or angioplasty during the early phase of acute MI in 787 patients. An abnormal SAECG was found to be predictive of an increased incidence of arrhythmias in all patients independent of prior thrombolytic therapy and/or angiography.

Denniss et al(46) studied a subset of patients with recent transmural MI without bundle branch block (n = 306) to determine the incidence of inducible ventricular tachyarrhythmia by programmed electrical stimulation and the prevalence of VLP (delayed ventricular activation times >140 ms after QRS onset) in post-MI patients.(44) Using frequency-domain SAECG, they found that 26 percent of patients with recent MI had VLPs detected by SAECG.

Do et al(47) in a retrospective study of 90 patients used time-frequency distributions to detect late potentials. Their results from the binomial transform were comparable to those from the standard time-domain criteria.

El-Sherif et al(34) conducted serial SAECG recordings in 156 patients up to 60 days after an acute MI and found that abnormal recordings during days 6-30 had the most significant relation to arrhythmias during the first year after an infarct.(32) They confirmed that early SAECG testing (within 5 days of an acute MI) or late development of an abnormality in the second month after infarction was not predictive of ventricular tachyarrhythmia in the post-MI period.

El-Sherif et al(48) also coordinated the recruitment of 1,211 post-MI patients at 10 medical centers. After excluding patients with bundle branch block, 1,158 patients were followed up for arrhythmic events for 1 year (10 ± 3 months) postinfarct. Through regression modeling with all clinical, Holter, and SAECG variables, the investigators found that the dQRS at 40 Hz at a cutpoint of >120 ms was the most significant predictor (p = 0.0001) of ventricular tachyarrhythmia. The positive predictive value, however, was only 17 percent. When combined with an abnormal Holter result and a left ventricular ejection fraction of <40 percent, the positive predictive value of dQRS rose to 32 percent. Negative predictive values of dQRS were consistently high for SAECG alone and improved when SAECG, Holter results, and left ventricular ejection fraction of <40 percent were added to the regression model.

Farrell et al(49) noted a 17 percent positive predictive value for SAECG while also showing that Killip Class II, heart rate variability, and left ventricular ejection fraction best predicted ventricular tachyarrhythmia when combined with SAECG.

Gomes et al(50) prospectively studied the prognostic significance of SAECG variables relative to other clinical variables and found that the predictive value of SAECG was equal to the left ventricular ejection fraction in patients with an inferior infarction and better than the left ventricular ejection fraction in patients with an anterior wall infarction. They calculated 5-month survival rates of 86 percent, and 72 percent in patients with ventricular tachyarrhythmia, <30 percent left ventricular ejection fraction, and positive SAECG, respectively.(48) In an earlier prospective study of SAECG in 102 patients, Gomes et al(51) concluded that the combination of an abnormal SAECG, an abnormal left ventricular ejection fraction, and the presence of high-grade ectopic activity was better in identifying high-risk patients than a single abnormal variable.

Hohnloser et al(52) prospectively studied 173 patients with an acute MI treated with thrombolysis. Late potentials were seen in 24 percent of patients. Multivariate analysis indicated that an occluded infarct-related artery and the presence of regional wall motion abnormalities were strong independent predictors for the development of VLPs.

Kuchar et al(53) performed SAECG during the hospitalization of 200 patients following an acute MI. Testing was performed 11 ± 6 days after initial presentation. Seventy-eight patients had an abnormal SAECG, a finding that identified 93 percent of patients with an arrhythmic event.

Mäkijärvi et al(54) studied 150 individuals: 26 patients with documented ventricular tachyarrhythmia (92 percent post-MI), 104 patients with acute MI without ventricular tachyarrhythmia, and 20 voluntary controls without evidence of heart disease. The purpose of this study was to determine the optimum filter settings that could be used to separate patients with and without ventricular tachyarrhythmia. All patients had decreased dQRS as the filter settings were increased from 25 Hz to 100 Hz, but the ventricular tachyarrhythmia group increased at all frequencies (p = 0.001). Sensitivity and specificity were simultaneously maximized (81 percent and 79 percent, respectively) by the dQRS parameter using a 25-Hz filter. The most sensitive single SAECG parameter was LAS50 using a 60-Hz filter. Logistic regression analysis demonstrated that the combined independent variables, dQRS, RMS50 using a 25-Hz filter, and LAS40 and RMS20 using a 80-Hz filter, were best at separating patients with ventricular tachyarrhythmia from those without ventricular tachyarrhythmia (X ^2^ = 33.4, p = 0.001).

Malik et al(55) recorded an SAECG in 553 survivors of acute MI before hospital discharge. SAECGs were analyzed using both time-domain and spectral turbulence analyses. Time-domain analysis was superior in predicting ventricular tachycardia/fibrillation during the first year of followup.

McClements and Adgey(56) found that ventricular tachyarrhythmia was best predicted by a combination of a positive SAECG, left ventricular ejection fraction (<40 percent), and the presence of congestive heart failure.

McGuire et al(36) performed SAECG every 48 hours in patients admitted to the hospital with an acute MI. The prevalence of a positive SAECG was 32 percent at presentation and increased progressively during hospital stay. A positive SAECG appeared to be useful in identifying patients at high risk of developing significant ventricular arrhythmias.

Mercando et al(57) performed SAECGs in 121 patients 6 months or more after an acute MI. All patients had complex ventricular arrhythmias. Forty-four patients had an abnormal SAECG, which alone was not predictive of mortality.

Pedretti et al(58) prospectively evaluated SAECGs in 303 survivors of acute MI. No single noninvasive prognostic variable was found valuable for identifying patients suitable for electrophysiologic studies. However, patients having both low left ventricular ejection fraction and a positive SAECG were considered eligible for programmed ventricular stimulation.

Reinhardt et al(59) evaluated the prognostic value of wavelet correlation functions of SAECGs in 769 men 2 to 3 weeks following an acute MI. The addition of wavelet correlation functions to SAECG analysis increased the prognostic value for significant arrhythmic events.

Richards et al(60) evaluated 225 patients 1-2 weeks following an acute MI and among the tests performed were electrophysiologic studies, left ventricular ejection fraction, SAECG, and Holter monitoring. The single best predictor of ventricular tachycardia or sudden death was inducible VT during electrophysiologic study.

Rodriguez et al(61) prospectively assessed 190 patients at varying intervals following a first acute MI. Sudden death was predicted only by left ventricular ejection fraction.

Steinberg et al(62) tested 182 consecutive patients after an acute MI. The risk associated with an abnormal SAECG was independent of left ventricular function and ventricular arrhythmias identified during Holter monitoring. Combined variables were found to be superior to single tests in identifying patients at high risk for VT or sudden death.

Turitto et al(27) found that the incidence of ventricular tachyarrhythmia during the first 2 months after an MI is not different in SAECG-positive and SAECG-negative patients.

Verzoni et al(63) prospectively studied the prognostic significance of SAECG in 220 survivors of an acute MI tested prior to hospital discharge and during the following year. SAECG was found to provide more prognostic information in identifying patients at risk for arrhythmic events than either Holter monitoring or left ventricular ejection function.

Zimmerman et al(64) assessed the effect of thrombolytic therapy on the incidence of ventricular late potentials in 223 consecutive patients surviving an acute MI. Incidence was indeed reduced, but its prognostic significance, however, required further study.

Recently, investigators, acknowledging the high number of false positives, have done sensitivity analyses of SAECG parameters to increase its sensitivity.(1, 2, 29-31, 37) However, operator-controlled variables and differences in SAECG component design do not permit an aggregated analysis because of variations in template matching, sampling frequency, filtering, baseline noise determinations, QRS onset and offset, the number of QRS complexes averaged, definitions of positive and negative SAECG, and the definitions of ventricular late potentials.

The clinical studies in Table 2 indicate that SAECG alone cannot accurately predict the occurrence of sustained ventricular tachyarrhythmia in post-MI patients. Positive predictive values in this table ranged from 8-44 percent, reflecting very high false-positive rates.

Others have reported positive predictive values ranging from 5-76 percent.(65) These wide ranges can be explained, in part, by variables in SAECG equipment and methodology. In contrast, the ability of SAECG to identify patients who remain free from sudden death or ventricular tachyarrhythmia during the post-MI period (up to 2 years) appears to be quite good (low false-negative rate and high negative predictive value). More than 10,000 MI patients have been studied using SAECG to identify patients at risk for sudden death or ventricular tachyarrhythmia.

In the series of prospective clinical studies in hospitalized post-MI populations reported in Table 2, VLPs were present in 9-58 (mean 24 percent) of patients. SAECGs high false-positive rates predicting sudden death or ventricular tachyarrhythmia lowered its positive predictive value for life-threatening arrhythmic events. This brings into question its use as an independent predictor of risk in this patient population, despite the one prospective case series that demonstrated positive SAECG to be an independent risk factor for future cardiac events.(4)

In a review of 15 studies by the American College of Cardiology, the negative predictive value of SAECG had a range of 88-99 percent with a median of 97 percent.(40) The positive predictive value had a median of only 17 percent (range 8-48 percent).

The clinical utility of a negative SAECG obviates the need for additional testing to identify patients at high risk of sustained ventricular tachyarrhythmia after MI. A positive SAECG in post-MI patients would mandate further testing to determine the risk of sustained ventricular tachyarrhythmia and/or sudden death.

In prospective clinical studies published since the 1991 SAECG standards, the predictive ability of SAECG has not improved. The preponderance of evidence continues to support the clinical utility of SAECG combined with the left ventricular ejection fraction in stratifying post-MI patients with ventricular arrhythmias for low or significant risk of ventricular tachyarrhythmia or sudden death.(48-50, 53, 56, 58)

### Cardiomyopathy

Patients with idiopathic dilated cardiomyopathies are prone to life-threatening arrhythmias and sudden death.(27, 49, 56, 66) SAECG has been used prospectively to predict survival in cardiomyopathy. Table 3 summarizes the results of published studies evaluating the use of SAECG in identifying patients with cardiomyopathy who are at increased risk of ventricular tachyarrhythmia and sudden death.

Table 3. Signal-averaged electrocardiography in patients with ischemic and nonischemic cardiomyopathies

Reference | Device | No. of patients | Mean followup days (range) | Frequency of endpoints (%)^a^ | No. +SAECG (%) during followup
Keeling(67) | ART 1200 EPX | 64 | 540±420 (30-1,350) | 5/64 (8) | 22/64 (34)
Kulakowski(68) | ART 1200 EPX | 121 | 180-480 (median 330) | 9/121 (7) | 30/121 (24)
Mancini(4) | ART 1200 EPX | 86 | 300±150 | 9/86 (10) | 20/86 (23)
Middlekauff(69) | Corozonix | 62 | 218±154 | 9/62 (14) | 19/62 (31)
Silverman(70) | Corozonix Predictor II | 200 | 597±437 | 43/135 (32) | 61/135 (48)
Turitto(71) | ART 1200 EPX | 80 | 654±771 | 9/80 (11) | 12/80 (15)
Vester(72) | Corozonix Predictor I | 157 | 360±180 | 9/157 (6) | 37/57 (24)
Yi(28) | ART 1200 EPX | 84 | 720±540 (30-1,770) | 28/84 (33) | 31/84 (37)

a Endpoints are SD (sudden death), VT (ventricular tachycardia), and MI (myocardial infarction).

Keeling et al(67) studied 64 consecutive patients with idiopathic, nonischemic, dilated cardiomyopathy with left ventricular hypertrophy, left ventricular ejection fractions of 28 ± 10 percent, and normal coronary arteries for 18 ± 14 months (range 1 to 45 months). They found positive predictive values of 88 percent and 57 percent in time-domain analysis (25- and 40-Hz filters, respectively) and 56 percent in spectral temporal mapping techniques in patients with any ventricular tachyarrhythmia. In patients with sustained ventricular tachyarrhythmia, the results were 38 percent, 21 percent, and 22 percent, respectively. Twenty-two patients had a positive SAECG during followup.

Kulakowski et al(68) studied 121 patients with hypertrophic cardiomyopathy who did not receive the antiarrhythmic drug, amiodarone. Patients were diagnosed by echocardiography, history, and physical examination. Both time- and frequency-domain SAECGs were done with 99 patients who had stopped taking antiarrhythmic medications. These patients were compared with a group of 44 age-matched controls. Seven percent of the patients had abnormal time-domain SAECGs. There were nine catastrophic events, eight of which occurred in men under the age of 30. Neither of the SAECG methods predicted these catastrophic events. The authors speculated that the mechanism for the sudden deaths was not ventricular tachyarrhythmia; thus, the poor positive predictive value of SAECG in cardiomyopathy.

Mancini et al(4) evaluated 86 patients with dilated nonischemic cardiomyopathy by time-domain SAECG. Patients were followed until death, sustained ventricular tachycardia (>120 beats per minute for >30 seconds), or a heart transplant. Twenty patients were SAECG-positive, and 66 patients had a normal SAECG. Mean followup time was 10 ± 5 months. Of the patients with left ventricular hypertrophy (39/86, 45 percent), most (36/39, 92 percent) had a normal SAECG. Patients with a normal SAECG had a 95-percent 1-year survival rate, and those with a positive SAECG had a 56 percent 1-year survival rate. Event-free (death, ventricular tachyarrhythmia, or urgent transplant) 1-year survival rate was 95 percent in the SAECG-negative group and 39 percent in the SAECG-positive group (p = 0.0001). Univariate analysis indicated abnormal SAECG, functional class, peak oxygen consumption, and history of ventricular tachyarrhythmia as the most significant variables (p = 0.0001 to p = 0.02). Multivariate predictors of any event were positive SAECG, functional class, cardiac index, standard QRS duration >120 ms, and age. As the authors of this study noted, although positive SAECG and functional class were independent predictors of death in patients with cardiomyopathy, left ventricular ejection fraction and peak exercise oxygen consumption were not (p = 0.62, p = 0.82, respectively). Explaining why these two parameters of left ventricular function were nonsignificant is difficult.

Middlekauff et al(69) concluded that the incidence of VLPs in a group of 62 patients depended on the etiology of the congestive heart failure. Late potentials were present in 31 percent of all patients and 40 percent of patients with evidence of an old MI but in only 3 percent of patients with nonischemic congestive heart failure.

Silverman et al(70) studied 200 patients with chronic congestive heart failure to investigate the relationship of heart failure to the results of the SAECG. Patient exclusions included permanent pacemaker or cardioverter/defibrillator insertion, or terminal illness. All patients were New York Heart Association (NYHA) Class II to IV (90 percent were Class III or IV). Cardiac catheterization or documented history of MI determined the diagnosis of ischemic cardiomyopathy, and all patients were prospectively stratified into normal SAECG (n = 74), abnormal SAECG (n = 61), or prolonged QRS (n = 65) categories. The investigators also divided the patients into ischemic (n = 88) or nonischemic (n = 112) groups. One of the few significant findings demonstrated that patients with nonischemic cardiomyopathy with a prolonged QRS have worse survival than the other two groups (p = 0.05). Patients with nonischemic disease with an abnormal SAECG had no worse a prognosis than patients with a normal SAECG. Patients with ischemic disease and an abnormal SAECG showed a trend toward a worse survival rate than that for those with a normal SAECG, but this was not statistically significant.

In an attempt to stratify for risk of arrhythmic events in a group of 80 patients with nonischemic dilated cardiomyopathy, Turitto et al(71) concluded that there is a strong correlation between an abnormal SAECG and induced ventricular tachyarrhythmia; however, both findings were uncommon in this subset of patients with only 15 percent exhibiting an abnormal SAECG.

Vester et al(72) in a study of 157 patients with dilated cardiomyopathy found a positive predictive value of only 24 percent and a negative predictive value of 93 percent.

In a group of at-risk patients with idiopathic dilated cardiomyopathies (n = 84), Yi et al(28) found that spectral turbulence analysis of SAECG (a newer frequency domain technique that detects frequent and abrupt changes in the QRS, permitting the assessment of the entire QRS complex) was no better than chance in predicting death (or aborted death) or progressive heart failure (54 percent, 50 percent, respectively). Of those patients with idiopathic dilated cardiomyopathies whose spectral turbulence analysis was considered abnormal (31/84, 37 percent), 18/31 (57 percent) experienced an adverse outcome during followup (mean 24 ± 18 months, range 1-59 months). Of the patients who did not remain clinically stable during followup (28/84, 34 percent), most had progressive heart failure (24/28, 85 percent), and the remainder died (4/28, 15 percent). Of those who survived, the spectral turbulence analysis was abnormal in 62 percent (15/24) of patients with idiopathic dilated cardiomyopathy. Of those who died, 75 percent were abnormal (3/4). Multivariate analysis determined that peak oxygen consumption (<19 mL/kg/min) presented the largest relative risk (9.55, 95 percent confidence interval [CI] 2.1-43.9) for the development of progressive heart failure in idiopathic dilated cardiomyopathic patients. Multivariate analysis also demonstrated that peak oxygen consumption, left ventricular end-diastolic dimension, and left ventricular ejection fractions were more likely to predict progressive heart failure than spectral turbulence analysis (relative risks were 6.43 [95 percent CI 1.28-32.4], 4.08 [95 percent CI 1.46-11.37], 3.35 [95 percent CI 1.01-1.28], and 3.2 [95 percent CI 1.04-9.08], respectively).

## Discussion

Ventricular tachyarrhythmia is known to be associated with an increased risk of cardiac death in the postinfarction period, with mortality rates approaching 60 percent. Proponents of SAECG have attempted to show that it is useful for risk stratification during recovery from MI. Many case series have reported SAECG, exercise testing, Holter monitoring, MUGA, programmed electrical stimulation, and coronary arteriography as useful for this purpose. In addition, supporting literature suggests radionuclide ventriculography to be a powerful predictor of survival. Other literature credits programmed electrical stimulation and Holter monitoring with being the best predictors of ventricular arrhythmic risk.

Results have been consistent in showing high negative predictive values (low false-negative rates) for adverse outcomes in post-MI patients with a negative SAECG. As mentioned previously, referral bias, case definitions, lack of randomization, and lack of masking of the investigators are probable methodologic flaws that may obscure generalizability of these results to different risk populations. Although other uses for SAECG have been proposed and carried out (such as in antiarrhythmic drug trials), the literature on post-MI patients is the most extensive to date.

The data supporting the use of SAECG in cardiomyopathic conditions were generated from small populations with ischemic and nonischemic conditions. Although a positive SAECG was not demonstrated to be an independent risk factor, two studies(28, 58) reported more morbidity (progressive heart failure, ischemia) in positive SAECG patients during followup. However, these studies were plagued by very high false-positive rates, which greatly diminished their value.

The data indicate that the SAECG in patients with cardiomyopathy has a weak positive predictive value and a strong negative predictive value. Conclusions about the value of SAECG in patients with cardiomyopathy, however, have been conflicting and may be explained in part by the variables in patient characteristics and the etiology of the myopathy.(13, 68, 70) Although SAECG has some prognostic value in patients with cardiomyopathy, a positive SAECG is a poor predictor of risk of sudden death in advanced cases. A 1995 review of the ability of SAECG to identify cardiomyopathy patients at high risk for sudden death concluded that, although SAECG is often abnormal in hypertrophic cardiomyopathy, it is not useful for risk stratification.(66)

Despite differences in SAECG component design and averaging techniques, several authors have demonstrated an increased risk of sudden death or ventricular tachyarrhythmia in SAECG-positive patients over patients who are SAECG-negative. The low sensitivity and poor predictive value of a positive SAECG present problems for clinicians in determining the utility of SAECG in both post-MI patients and those with cardiomyopathy.(50) Until the false-positive rate for SAECG can be reduced, independent confirmation of myocardial risk by other invasive or noninvasive methods appears to be prudent. SAECG alone appears unlikely to help in stratifying patients for further diagnostic or treatment interventions, but it does appear to serve for such discrimination after acute MI when combined with left ventricular ejection fraction.

Multivariate testing appears to be superior to univariate testing, and results of SAECG post-MI appear to differ depending on when it is performed. However, the optimal time to perform SAECG post-MI has not been determined.(1, 34, 44, 49, 53, 56, 58)

### U.S. Public Health Service Comments

Based on the clinical data submitted to the Food and Drug Administration (FDA), through premarket notifications, the evidence to justify the claim that the performance of SAECG affects health outcomes is insufficient. However, based on expert consensus (e.g., the American College of Cardiology expert consensus document published in J Am Coll Cardiol 1996;27:238-249), the FDA believes that, for patients recovering from MI, SAECG has proven negative predictive accuracy when used to assess risk for development of life-threatening ventricular arrhythmias. The positive predictive accuracy of SAECG alone is not yet established.

The National Institutes of Health believe that SAECG is a safe and effective technology that can be clinically useful when combined with other standard tests to stratify risk of ventricular tachycardia in post-MI patients. The negative value has clinical significance because it can obviate the need for additional tests. Further study is required to confirm the use of SAECG in the surgical treatment of ventricular arrhythmias, detection of cardiac transplant rejection, early recognition of reperfusion after acute MI, and monitoring of antiarrhythmic drug treatment.

## Conclusion

A wide variety of signal-averaging methods continue to be used. However, time domain is the primary tool for SAECG analysis. Although definitions of late potentials are still not standardized,(73) their identification has improved, and their prognostic value for clinically significant arrhythmias has been demonstrated after MI. Prognostication is enhanced when late potential analysis is combined with other tests such as left ventricular ejection fraction, Holter monitoring, or programmed electrical stimulation.

Several consistent results have been observed from the SAECG clinical studies: 1) a very high negative predictive value (76-100 percent); 2) variable sensitivity (35-83 percent) and specificity (47-91 percent); and 3) poor positive predictive value (8-48 percent) in at-risk populations. Many studies have demonstrated higher adverse effects in patients with positive VLPs or positive SAECG after MI than in those with negative VLPs. The prevalence of VLP was highest at 6 weeks to 3 months post-MI.

Given the inherent differences and lack of standardization in operating principles, institutional variances in methodology, and patient selection criteria, the routine use of SAECG as a univariate indicator of risk remains to be proven. In addition, the reproducibility of SAECG has been problematic.(74) Efforts that have been underway for the past 10 years in attempting to establish and sustain a unique role for SAECG technique have not been successful, despite the high negative predictive values, which can reduce the need for additional testing in patients with other single risk factors.

The preponderance of evidence suggests that other diagnostic measurements, such as left ventricular ejection fraction and programmed electrical stimulation, are useful in identifying patients at risk for ventricular tachyarrhythmia and sudden death. The acute MI and the cardiomyopathy literature have repeatedly demonstrated that the functional state of the left ventricle, whether compromised by ischemic or nonischemic processes, reliably predicts future risk (sudden death, ventricular tachyarrhythmia).(28) However, none of these modalities is sufficiently accurate as a univariate predictor or consistently better than SAECG. These modalities are perhaps most appropriately used in combination.(27, 34, 49, 53, 58)

A negative SAECG in the immediate post-MI period is associated with a lower morbidity and mortality in the first year post-MI. However, any conclusions about the prognostic value or utility of SAECG alone should await the results of ongoing prospective clinical trials on SAECG.

Patients with a positive SAECG have other risk factors, such as coronary artery disease, ventricular tachyarrhythmia, reduced left ventricular function, ventricular tachyarrhythmia on Holter monitoring, and other inducible arrhythmias. The high false-positive SAECG rate may obscure its utility when used alone. A positive SAECG, when combined with other standard tests, has been demonstrated to have clinical utility in post-MI patients. Other patient populations have not been conclusively shown to benefit from its use.

## References

1 Breithardt G, Cain M, El-Sherif N, et al Standards for analysis of ventricular late potentials using high resolution or signal-averaged electrocardiography. A statement by a task force committee of the European Society of Cardiology, the American Heart Association, and the American College of Cardiology Circulation 1991 83 (4):1481 1488 2013173
2 Gomes JA The signal averaged ECG: a historical perspective, in Gomes JA. (Ed): Signal averaged electrocardiography: concepts, methods and applications, Boston: Kluwer Academic Publishers, 1993
3 Chang-Sing P, Peter CT Syncope: evaluation and management Cardiology Clinics 1991 9 (4):641 651 1811870
4 Mancini DM, Wong KL, Simson MB Prognostic value of an abnormal signal-averaged electrocardiogram in patients with nonischemic congestive cardiomyopathy Circulation 1993 87:1083 1092 8462136
5 McCall D Acute myocardial infarction, New York: Churchill Livingstone, 1991
6 Figueredo VM, Amidon TM, Wolfe CL Thrombolysis after acute myocardial infarction. Adjuvants to thrombolysis after acute myocardial infarction. Does adding antiplatelet agents, antithrombotics, or angioplasty make a difference? Postgrad Medicine 1994 96 (8):30 40
7 Shen WK, Hammill SC Survivors of acute myocardial infarction: who is at risk for sudden cardiac death? Mayo Clin Proc 1991 66:950 962 1921506
8 Bigger JT, Fleis Fleiss JL, Kleiger R, et al The relationships among ventricular arrhythmias, left ventricular dysfunction and mortality in the 3 years after myocardial infarction Circulation 1984 69:250 257 6690098
9 Kostis JB, Byington R, Friedman JM, et al Prognostic significance of ventricular ectopic activity in survivors of acute myocardial infarction J Am Coll Cardiol 1987 10:231 242 2439559
10 Chiriboga D, Yarzebski J, Goldberg RJ, et al Temporal trends (1975 through 1990) in the incidence and case fatality rates of primary ventricular fibrillation complicating acute myocardial infarction Circulation 1994 89:998 1003 7880217
11 Eldar M, Sievner Z, Goldbourt U, et al Primary ventricular tachycardia in acute myocardial infarction: clinical characteristics and mortality Ann Int Med 1992 117:31 36 1596045
12 Cobb LA The mechanisms, predictors, and prevention of sudden cardiac death, in Hurst JW, Schlant RC. (Eds): The heart: arteries and veins, New York: McGraw-Hill, Inc., 1990
13 Nisam S, Thomas A, Mower M, et al Identifying patients for prophylactic automatic implantable cardioverter defibrillator therapy: status of prospective studies Am Heart J 1991 122 (2):607 612 1858656
14 Hutter AM Cardiac tachyarrhythmias: basic aspects and pharmacological therapy Scient Am Med 1995 1 (V):
15 O'Rourke RA Overview of trends in heart disease: changing prognosis after myocardial infarction Ann Epidemiol 1993 3 (5):541 546 8167834
16 Mattioni TA Long term prognosis after myocardial infarction Postgrad Med 1992 92 (8):107 114 1454663
17 Connolly SJ, Cairns JA Prevalence and predictors of ventricular premature complexes in survivors of acute myocardial infarction Am J Cardiol 1992 69:408 413 1370871
18 Echt DS, Liebson PR, Mitchell B, et al Mortality and morbidity in patients receiving encainide, flecainide or placebo: the cardiac arrhythmia suppression trial New Engl J Med 1991 324 (12):781 788 1900101
19 Winters SL, Gomes JA A practical guide to signal-averaged electrocardiography and late potential analysisPrepared for Arrhythmia Research Technology, Inc.,, 5910 Courtyard Drive, Suite 300, Austin, TX 78731; 1990 (Unpublished in a peer-reviewed journal.)
20 Breithardt G, Borggrefe M, Haerten K Ventricular late potentials and inducible ventricular tachyarrhythmias as a marker for ventricular tachycardia after myocardial infarction Eur Heart J 1986 7 (Suppl A):127 134 3720767
21 Breithardt G, Borggrefe M, Haerten K Role of programmed ventricular stimulation and noninvasive recording of ventricular late potentials for the identification of patients at risk of ventricular tachyarrhythmias after acute myocardial infarction, in: Cardiac Electrophysiology and Arrhythmias (Chapter 63), New York: Grune and Stratton, 1985 pp 553 561
22 Walter PF Technique of electrophysiological testing, in Hurst JW, Schlant RC, Rackley. (Eds): The heart: arteries and veins, New York: McGraw-Hill, Inc., 1990 pp 1846 1853
23 Kjellgren O, Gomes JA Current usefulness of the signal-averaged electrocardiogram, in O'Rourke RA, McCall D. (Eds): Current problems in cardiology 1993 18 (6):
24 Simson MB Signal averaged electrocardiography, in Zipes DP, Jalife J. (Eds): Cardiac electrophysiology: from cell to bedside, Philadelphia: W.B. Saunders Co., 1990 pp 807 817
25 Simson MB The role of signal averaged electrocardiography in identifying patients at high risk for lethal ventricular tachyarrhythmias PACE 1991 14 (2):944 952 1712465
26 Jarrett JR, Flowers NC Signal averaged electrocardiography: history, techniques and clinical applications Clin Cardiol 1991 14:984 1994 1841024
27 Turitto G, Caref EB, Macina G, et al Time course of ventricular arrhythmias and the signal averaged electrocardiogram in the post-infarction period: a prospective study of correlation Br Heart J 1988 60:17 22 3408615
28 Yi G, Keeling PJ, Goldman JH, et al Prognostic significance of spectral turbulence analysis of the signal averaged electrocardiogram in patients with idiopathic dilated cardiomyopathy Am J Cardiol 1995 75:494 497 7863996
29 Caref EB, El-Sherif N The role of filtering in the analysis of signal averaged electrocardiography, in El-Sherif N, Turitto G. (Eds): High resolution electrocardiography, Mount Kisco: Futura Publishing Co., 1992
30 Haberl R, Steinbigler P, Jilge G Spectral analysis of high resolution ECG: current concepts and future directions PACE 1994 17:446 450 7513872
31 Kelen GJ, Henkin R, Starr AM, et al Spectral turbulence analysis of the signal-averaged electrocardiogram and its predictive accuracy for inducible sustained monomorphic ventricular tachycardia Am J Cardiol 1991 67:965 975 2018016
32 Borbola J, Denes P Oral amiodarone loading therapy. I. The effect on signal averaged electrocardiographic recordings and the Qtc in patients with ventricular arrhythmias Am Heart J 1988 115:1202 1208 3376837
33 Kulakowski P, Gibson S, Ward J, et al Flecainide related alterations in the signal averaged electrocardiograms: similarity between patients with or without ventricular tachycardia Eur Heart J 1992 13:808 813 1623872
34 El-Sherif N, Ursell S, Bekheit S, et al Prognostic significance of the signal averaged ECG depends on the time of recording in the postinfarction period Am Heart J 1989 118:256 264
35 Leclercq JF, Coumel P Late potentials in arrhythmogenic right ventricular dysplasia: prevalence, diagnostic and prognostic values Eur Heart J 1993 14:80 83 8223760
36 McGuire M, Kuchar D, Ganis J, et al Natural history of late potentials in the first ten days after acute myocardial infarction and relation to early ventricular arrhythmias Am J Cardiol 1988 61:1187 1190 3376880
37 Malik M, Kulakowski P, Odemuyiwa O, et al Effect of thrombolytic therapy on the predictive value of signal-avegared electrocardiography after acute myocardial infarction Am J Cardiol 1992 70:21 25 1615864
38 Bhatnagar SK Signal-averaged electrocardiography in survivors of first acute myocardial infarction: a pre-hospital discharge study Indian Heart J 1995 47:353 359 8557278
39 Ommen SR, Hammill SC, Bailey KR Failure of signal averaged electrocardiography with use of time domain variables to predict inducible ventricular tachycardia in patients with conduction defects Mayo Clin Proc 1995 70:132 136 7845038
40 [Cain ME, Anderson JL, Arnsdorf MF, et al.] ACC expert consensus document. Signal-averaged electrocardiography J Am Coll Cardiol 1996 27:238 249 8522703
41 Ahuja RK, Turitto G, Ibrakin B, et al Combined time-domain and spectral turbulence analysis of the signal-averaged ECG improves its predictive accuracy in postinfarction patients J Electrocardiol 1994 27s:202 206 7884362
42 Brembilla-Perrot B, de la Chaise AT, Briancon S, et al Programmed ventricular stimulation in survivors of acute myocardial infarction Int J Cardiol 1995 49:55 65 7607767
43 Cripps T, Bennett D, Camm J, et al Prospective evaluation of clinical assessment, exercise testing and signal averaged electrocardiogram in predicting outcome after acute myocardial infarction Am J Cardiol 1988 62:995 999 3189192
44 de Chillou C, Rodriguez L, Doevendans R, et al Factors influencing changes in the signal-averaged electrocardiogram within the first year after a first myocardial infarction Am Heart J 1994 128:263 70 8037092
45 Denes P, El-Sherif N, Katz R, et al Prognostic significance of signal-averaged electrocardiogram after thrombolytic therapy and/or angioplasty during acute myocardial infarction (CAST substudy) Am J Cardiol 1994 74:216 220 8037124
46 Denniss AR, Richards DA, Cody DV, et al Prognostic significance of ventricular tachycardia and fibrillation induced at programmed stimulation and delayed potentials detected on the signal-averaged electrocardiograms of survivors of acute myocardial infarction Circulation 1986 74:731 745 3757187
47 Do TM, Rubal BJ, Bulgrin JR, et al Time-frequency analysis of ECG for late potentials in sudden cardiac death survivors and post-myocardial infarction patients Biomed Sci Instrument 1995 31:109 114
48 El-Sherif N, Denes P, Katz R, et al Definition of the best prediction criteria of the time domain signal averaged electrocardiogram for serious arrhythmic events in the post infarction period J Am Coll Cardiol 1995 25:98 104
49 Farrell TG, Bashir Y, Cripps T, et al Risk stratification for arrhythmic events in postinfarction patients based on heart rate variability, ambulatory electrocardiographic variables and the signal-averaged electrocardiogram J Am Coll Cardiol 1991 18:687 797 1822090
50 Gomes JA, Winters SL, Martinson M, et al The prognostic significance of quantitative signal-averaged variables relative to clinical variables, site of myocardial infarction, ejection fraction and ventricular premature beats: a prospective study J Am Coll Cardiol 1989 13:377 384 2464014
51 Gomes JA, Winters SL, Stewart D, et al A new noninvasive index to predict sustained ventricular tachycardia and sudden death in the first year after myocardial infarction: based on signal-averaged electrocardiogram, radionuclide ejection fraction and Holter monitoring J Am Coll Cardiol 1987 10:349 457 3598005
52 Hohnloser SH, Frank Franck P, Klinzenheben T, et al Open infarct [artery], late potentials and other prognostic factors in patients after acute myocardial infarction in the thrombolytic era. A prospective trial Circulation 1994 90:1747 1756 7923658
53 Kuchar DL, Thorburn CW, Sammel NL Prediction of serious arrhythmic events after myocardial infarction: signal-averaged electrocardiogram, Holter monitoring and radionuclide ventriculography J Am Coll Cardiol 1987 9:531 538 3819200
54 Mäkijärvi M, Montonen J, Toivonen L, et al High-resolution and signal-averaged electrocardiography to separate post-myocardial infarction patients with and without ventricular tachycardia Eur Heart J 1994 15:189 199 8005119
55 Malik M, Kulakowski P, Hnatkova K, et al Spectral turbulence analysis versus time-domain analysis of the signal averaged ECG in survivors of acute myocardial infarction J Electrocardiol 1994 27s:227 232 7884366
56 McClements BM, Adgey JAA Value of signal-averaged electrocardiography, radionuclide ventriculography, Holter monitoring and clinical variables for prediction of arrhythmic events in survivors of acute myocardial infarction in the thrombolytic era J Am Coll Cardiol 1993 21:1419 1427 8473651
57 Mercando AD, Aronow WS, Epstein S, et al Signal averaged electrocardiography and ventricular tachycardia as predictors of mortality after acute myocardial infarction in elderly patients Am J Cardiol 1995 76:436 440 7653440
58 Pedretti R, Etro MD, Laporta A, et al Prediction of late arrhythmic events after acute myocardial infarction from combined use of noninvasive prognostic variables and inducibility of sustained monomorphic ventricular tachycardia Am J Cardiol 1993 71:1131 1141 8480637
59 Reinhardt L, Makijarvi M, Fetsch T, et al Predictive value of wavelet correlation functions of signal-averaged electrocardiogram in patients after anterior versus inferior myocardial infarction J Am Coll Cardiol 1996 27:53 59 8522710
60 Richards DA, Byth K, Ross DL, et al What is the best predictor of spontaneous ventricular tachycardia and sudden death after myocardial infarction? Circulation 1991 83:756 763 1999026
61 Rodriguez LM, Krijne R, van del Dool A, et al Time course and prognostic significance of serial signal averaged electrocardiograms after a first myocardial infarction Am J Cardiol 1990 66:1199 1202 2239722
62 Steinberg JS, Regan R, Sciacea RR, et al Predicting arrhythmic events after acute myocardial infarction using the signal averaged electrocardiogram Am J Cardiol 1992 69:13 21 1530900
63 Verzoni A, Romano S, Pozzoni L, et al Prognostic significance and evolution of late ventricular potentials in the first year after myocardial infarction: a prospective study PACE 1989 12:41 51 2464810
64 Zimmerman Zimmermann M, Adamec R, Ciaroni S Reduction in the frequency of ventricular late potentials after acute myocardial infarction by early thombolytic therapy Am J Cardiol 1991 67:697 703
65 Craceffo Graceffo MA, O'Rourke RA, Hibner C, et al The time course and relation of positive signal-averaged electrocardiograms by time-domain and spectral temporal mapping analyses after infarction Am Heart J 1995 129:238 251 7832095
66 Chang AC, McAreavey D, Fananapazir L Identification of patients with hypertrophic cardiomyopathy at high risk for sudden death Curr Opinion Cardiol 1995 10:9 15
67 Keeling PJ, Kulakowski P, Yi G Usefulness of signal-averaged electrocardiogram in idiopathic dilated cardiomyopathy for identifying patients with ventricular arrhythmias Am J Cardiol 1993 72:78 84 8517433
68 Kulakowski P, Counihan PJ, Camm AJ, et al The value of time and frequency domain, and spectral temporal mapping analysis of the signal-averaged electrocardiogram in the identification of patients with hypertrophic cardiomyopathy at increased risk of sudden death Eur Heart J 1993 14:941 950 8375420
69 Middlekauff HR, Stevenson WG, Woo MA, et al Comparison of frequency of late potentials in idiopathy idiopathic dilated cardiomyopathy and ischemic cardiomyopathy with advanced congestive heart failure and their usefulness in predicting sudden death Am J Cardiol 1990 66:1113 1117 2220639
70 Silverman ME, Pressel MD, Brackett JC, et al Prognostic value of the signal-averaged electrocardiogram and a prolonged QRS in ischemic and nonischemic cardiomyopathy Am J Cardiol 1995 75:460 464 7863989
71 Turitto G, Ahuja RK, Caref EB, et al Risk stratification for arrhythmic events in patients with nonischemic dilated cardiomyopathy and nonsustained ventricular tachycardia: role of programmed ventricular stimulation and the signal-averaged electrocardiogram J Am Coll Cardiol 1194 24:1523 1528 7930285
72 Vester EG, Emschermann C, Stabbe U, et al Late potentials and heart rate variability in heart muscle disease Eur Heart J 1994 15s:25 33 7995267
73 Lander P, Berbari EJ, Rajagopalan CV, et al Critical analysis of the signal averaged electrocardiogram: improved identification of late potentials Circulation 1993 87:105 117 8418997
74 Aganauskiene J, Sornmo L, Atarius R, et al Reproducibility of the signal-averaged electrocardiogram using individual lead analysis Eur J Heart 1995 16:1244 1254