# Institutional and Patient Criteria for Heart-Lung Transplantation

Health Technology Assessment, Number 1

## Foreword

The Office of Health Technology Assessment (OHTA) evaluates the risks, benefits, and clinical effectiveness of new or unestablished medical technologies. In most instances, assessments address technologies that are being reviewed for purposes of coverage by federally funded health programs.

OHTA's assessment process includes a comprehensive review of the medical literature and emphasizes broad and open participation from within and outside the Federal Government. A range of expert advice is obtained by widely publicizing the plans for conducting the assessment through publication of an announcement in the Federal Register and solicitation of input from Federal agencies, medical specialty societies insurers, and manufacturers. The involvement of these experts helps ensure inclusion of the experienced and varying viewpoints needed to round out the data derived from individual scientific studies in the medical literature.

After OHTA receives information from experts and the scientific literature, the results are analyzed and synthesized into an assessment report. Each report represents a detailed analysis of the risks, clinical effectiveness, and uses of new or unestablished medical technologies. If an assessment has been prepared to form the basis for a coverage decision by a federally financed health care program, it serves as the Public Health Service's recommendation to that program and is disseminated widely.

OHTA is one component of the Agency for Health Care Policy and Research (AHCPR), Public Health Service, Department of Health and Human Services.

- Thomas V. Holohan, M.D.
- Director
- Office of Health Technology Assessment
- J. Jarrett Clinton, M.D. Administrator
- Agency for Health Care Policy and Research
- Questions regarding this assessment should be directed to:
- Office of Health Technology Assessment
- AHCPR
- Willco Building, Suite 309
- 6000 Executive Boulevard
- Rockville, MD 20852
- Telephone: (301)594-4023

## Introduction

During the past 40 years, there have been remarkable developments in surgical skills and techniques. The advent of reliable heart-lung bypass machines and advances in anesthesia, immunology, and the use of hypothermia during surgery have made heart (HT) and heart-lung transplantation (HLT) technically possible.(1-2) Moreover, in the late 1970s, with greater understanding of the immune system and the discovery of new and powerful immunosuppressants such as cyclosporine and antilymphocyte globulins, it became possible to inhibit much of the host rejection response to these allografts.(4) Consequently, for the past 10 years, HLTs have been performed with greater success. However, this operation is expensive and labor and resource intensive, and the supply of suitable donor organs is very limited.

## Background

The first animal HLTs were performed in the United States in the early By the late 1960s, sporadic attempts to perform HLTs in humans were reported; however, most recipients survived for only a few days.(1-3) In 1982, surgeons at Stanford University performed three HLTs using cyclosporine for immunosuppression. Two of the first three patients were reported, at the time of publication, to have survived for 8 and 10 months, respectively.(5) Since 1981, several hundred patients in the United States have had (6). There were 73 HLT procedures performed in 1988, but there has been a decrease in successive years to 48 in 1992. This decrease in HLTs is due to the fact that some of the clinical conditions in which HLT had been used are now being treated by single-and double-lung transplantation (LT) (7) Between 1988 and 1992, 49 institutions performed 278 HLTs. There is, however, a substantial concentration of experience. Six institutes have done 6 to 12 HLTs, six institutes have performed 12 or more HLTs, and the remaining 37 institutions have performed fewer than six each. (Data provided by the United Network for Organ Sharing [UNOS] to the Health Resources and Services Administration; Nelson JL, memorandum, April 23, 1993.)

HLTs have been performed most often in patients with primary pulmonary hypertension, Eisenmenger's syndrome or other congenital heart disease, cystic fibrosis, and emphysema. HLT has been performed less often for diseases such as sarcoidosis, lupus, eosinophilic granulomatosis, asbestosis, histiocytosis, and idiopathic pulmonary fibrosis. The estimated cost for HLT in 1990 was $152,000.(8)

The frequency of this operation is in part limited by the number of suitable donor organs available. In the case of HLT, there are fewer suitable donor heart-lung preparations available than there would be for HT alone because brain death itself may be associated with neurogenic pulmonary edema; similarly, aspiration into the lungs is frequent during the course of severe trauma and resuscitation. Prolonged ventilatory support may predispose the potential donor to nosocomial infection, and direct thoracic trauma may result in pulmonary contusion. As a consequence, probably less than 20 of potential heart donors have lungs that are suitable for HLT.(9) In addition, successful lung preservation has been difficult to achieve for extended periods. After removal from the donor, the heart and lungs can be kept in a suitable condition for transplantation for only 4 to 5 hours. This short time frame presents formidable logistic hurdles for the surgical teams involved.(9,10) However, HLT has been described in some ways as a technically easier procedure than HT, since HLT requires only right atrial, aortic, and tracheal anastomoses and thus avoids several of the anastomoses associated with HT.(9)

The transplantation of organs in the United States has been facilitated by the establishment of an organ donor-recipient matching system established by the National Organ Transplant Act of 1984 (PL 98-507). This system is called the Organ Procurement and Transplantation Network (OPTN). OPTN also coordinates the transportation of organs and collects, analyzes, and publishes data regarding organ donation.(6)

In 1987, the Health Resources and Services Administration (HRSA) of the Public Health Service awarded the contract to implement PL 98-507 to UNOS.

Issues concerning patient selection criteria and institutional selection criteria for HT, an operation that is technically and logistically similar to HLT, arose in the mid-1980s. At that time, the National Heart, Lung, and Blood Institute of the National Institutes of Health (NIH) and the Battelle Memorial Institute developed such criteria. These were then adopted by the Health Care Financing Administration (HCFA) in 1987 as criteria for certification of Medicare-approved HT centers.(11) These criteria for HT may offer some guidance for the establishment of patient and institutional selection criteria for HLT.

## Review of Available Information

Published articles were retrieved through the MEDLINE system of the National Library of Medicine. Literature published in the English language between 1978 and 1992 was screened using the key words "heart-lung transplant" and "human." Two hundred twenty-seven articles were identified. Excluded from this evaluation were review articles of a general nature, correspondence, and case reports of individual patients; this resulted in the selection of 34 published reports. Additional material reviewed included textbooks and relevant personal communications forwarded to the Office of Health Technology Assessment (OHTA).

The published clinical reports of HLTs are all case series. They did provide information regarding patient diagnosis, outcomes, and survival rates, but were heterogeneous and vague in regard to the specific medical indications for which HLTs were performed, the way in which the survival data were calculated, the manner in which postoperative deaths were defined, and the number of patients reported in individual papers (this ranged from 2 to 152).

### Patient Selection Criteria

Selected published studies of HLT are summarized in Table 1. (5,12-22). Compilations of such medical conditions as well as contraindications to HLT have been extracted from these and other studies (3,5,12-36). and from a personal communication (Starnes VA, Stanford University, August 1990). They are listed in outline form in Tables 2 and 3, respectively.

Table 1. Case series, heart-lung transplantation

Reference | Year | No. of patients | Diseases for which HLTs were performed | Deaths within 30 d | Deaths within 60 d | Length of followup, mo | Survival rate
5 | 1982 | 3 | PPH, ES, TGV | 1 | 1 | 8-10 | 67, 8 and 10 mo
12 | 1986 | 12 | ES | 3 | 4 | 7-44 | 2 died at 14 and 15 mo; 6 were alive 7-44 mo
13 | 1987 | 31 | ES, E, B, PPH, CF, C, H | 1 | 4 | 2-43 | 78 at 1 y, 70 at 2 y [*]
14 | 1988 | 7 | PF, CF, ES, H, B, S | 0 | 1 | 4-33 | 86 at a median of 11 mo
15 | 1989 | 51 | ES, PPH, CF, E, and several other conditions | 5 | 8 | 1-54 | 76 at 1 y, 68 at y [*]
16 | 1989 | 2 | Pulmonary thrombosis with pulmonary infarction and bronchiectasis with right-sided heart failure | 1 | 1 | 4 | 50 at 4 mo
17 | 1989 | 7 | PPH, ES | 0 | 0 | 3-34 | 100 at mean followup of 15 mo
18 | - 1990 | - 15 HLT; - 5 SLT; - 2 DLT | PPH, CF, PF, E | 2 (both HLT) | 2 | 3-22 | 55 at 3-22 mo [\|]
19 | 1990 | 17 | CF | 0 | 3 | 1-46 | 82 at mean followup of 14 mo
20 | 1990 | 152 | PPH, ES, E, CF, and several other conditions | Hospital mortality rate (32.2) | NS | 64 at 1 y, 61 at 2 y [*]
21 | - 1990 | - 30 (group 1) [\|\|]; - 32 (group 2) | - CF, OB, PPH, ES; - CF, OB, PPH, ES | - 9; - 1 | - 11; - 5 | - NS; - NS | - For years 1-6, the actuarial survival rates were 60, 50, 43, 40, 25, and 13; - For years 1-3, the actuarial survival rates were 73, 73, and 65
22 | 1991 | 11 | E | 1 | 1 | 12-53 | 91 at 1 y [*]
23 | 1991 | 11 [**] | CF | 1 | 2 | 1.5-23 | 6 surviving patients (55). Survived from 1.5-23 mo
24 | 1991 | 10 [***] | ES, PPH, CF | 2 perioperative deaths at 3 and 4 mo | 24 | 78 at 1 y and 47 at 2 y [*]
25 | 1991 | 32 | CF | 4 | 6 | 53 | 72 at 1 y, 58 at 2 y, and 56 at 3 y [*]
26 | 1992 | 79 | CF | 12 | 18 | 66 | 69 at 1 y, 52 at 2 y, and 49 at 3 y [*]

* Actuarial survival rate.

| Data combines HLT, SLT, and DLT.

|| In this study, the 62 patients were broken into two groups: group 1 was operated on earlier than group 2, and the two groups had different regimens of immunosuppression.

** All patients were children, 5-15 years of age.

*** Patients were children and adolescents (4 months to 18 years of age).

Abbreviations: B = bronchiectasis; C = cardiomyopathy; CF = cystic fibrosis; DLT = double-lung transplantation; E = emphysema; ES = Eisenmenger's syndrome; H = histiocytosis X; HLT = heart-lung transplantation; NS = not stated; OB = obliterative lung disease; PF = pulmonary fibrosis; PPH = primary pulmonary hypertension; S = sarcoidosis; SLT = single-lung transplantation; TGV = transposition of great vessels.

Table 2. Medical conditions treated by heart-lung transplantation

Pulmonary vascular disease: | - Primary pulmonary hypertension; - Eisenmenger's syndrome or complex; - Pulmonary hypertension secondary to thromboembolic disease; - Cardiomyopathy with pulmonary hypertension
Obstructive lung disease: | - Emphysema-idiopathic; - Emphysema in [alpha](1)-antitrypsin deficiency; - Cystic fibrosis; - Bronchiectasis; - Bronchopulmonary dysplasia; - Posttransplant obliterative bronchiolitis
Restrictive lung disease: | - Idiopathic pulmonary fibrosis; - Sarcoidosis; - Asbestosis; - Histiocytosis X; - Bronchiolitis obliterans; organized pneumonia; - Lymphangioleiomyomatosis; - Lupus; - Eosinophilic granulomatosis
Subsequent operation for failure of original graft

SOURCE: From References 3, 5, and 12-36 and Starnes VA, Stanford University (personal communication, August 1990).

Table 3. Cited contraindications to heart-lung transplantation

- Significant systemic or multisystem disease [*]; - Significant renal disease; creatinine clearance <50 mL/min; - Current cigarette smoking [*]; - Psychiatric illness [*]; - Drug or alcohol abuse [*]; - HIV [\|] positivity [*]; - Corticosteroid therapy [*]; - Bilirubin >3.5 mg/dL; - Extrapulmonary or pulmonary infection; - Significant hepatic disease; - Cachexia or obesity; - Previous cardiothoracic surgery (may be considered on a case-by-case basis); - Absence of a suitable family structure to provide psychologic, physical, and financial support to the patient; - Age >55 y

* More serious contraindications.(37)

| Human immunodeficiency virus.

SOURCE: From References 12-36 and Starnes VA, Stanford University (personal communication, August 1990).

Several of the authors cited in Table 1 and in References 3, 5, and 23-32 and in the personal communication from Starnes indicated that suitable candidates should have the following general characteristics: They should have a life expectancy of only 6 to 12 months with a deteriorating course, should be unresponsive to medical therapy, and should be severely disabled, e.g., the New York Heart Association's functional classification III or IV (class III = comfort is present at rest, but less than ordinary physical activity results in dyspnea or fatigue; class IV = dyspnea or fatigue may be present at rest and is made worse by any physical effort). Patients should have no other serious medical problems, and they should be psychologically willing to undergo the stressful surgery and postoperative care necessary for a successful

Few of the reports shown in Table 1 (5,12-26). provide cardiac or pulmonary functional criteria in the form of actual numerical values that quantitate the degree of disability. Rather, terms such as "increased pulmonary artery pressure," "cardiomegaly," and "corpulmonale" are used. In addition, appropriate patient ages have been specified as follows: 5 to 45 years of age, younger than 50, and no older than 60 years of age. Preoperative prognosis has been specified as expected survival of less than 6 months, "severely disabled," "poor prognosis," and "deteriorating clinical condition." Thus, the patient selection criteria for HLT are not defined in any quantitative, systematic, or uniform manner in the published literature.

Another source of information relevant to criteria for patient selection was a report in 1991 by Evans et al in the National Cooperative Transplantation (37). This was an opinion survey carried out at 366 transplant programs in the United States. The survey indicated that the respondents believed that among the more severe contraindications for HLT were human immunodeficiency virus (HIV) antibody positivity, chronic renal failure, a recent history of intravenous drug abuse, a history of cerebrovascular accidents resulting in significant impairment, treatment with 50 mg or more of prednisone per day, Down's syndrome, active smoking, primary heart or lung malignancy, history of noncompliance with medical regimens, recurrent pulmonary emboli, and an age over 60.

It should be noted that the patient selection criteria for HLT are in flux, partly because a number of diseases previously treated with HLT can now be treated by LT.(7,38)

### Patient Factors

Comprehensive registries contain far more data on patient survival following HLT, diagnosis, and age than do published case studies. Data from registries are often more current than those from the published literature, and the data set from the international registry is larger than that from the United States alone. This type of information cannot be obtained easily from reports such as those cited in Table 1, because each case series contains only a relatively small number of patients with a particular diagnosis, and information on long-term outcome is limited by the duration of patient followup prior to publication.

Tables 4and 5Table 4

Table 4. Kaplan-Meier survival analysis for heart-lung transplantation: Worldwide data, January 1981-June 1991

Interval, mo | Survivals | Mortalities | Censored [*] | Survival
0 | 1,056 | 0 | NA [\|]; | 100.00
12 | 560 | 449 | 47 | 57.20
24 | 370 | 508 | 178 | 50.29
36 | 242 | 529 | 285 | 46.98
60 | 84 | 548 | 424 | 41.05

* Statistical estimation of a parameter, such as the probability of survival, depends on the amount of information available for analysis. In this case, the patients for whom complete data are not available for the latest time interval shown (60 months) are annotated in the "censored" column.

| Not applicable.

SOURCE: From the Registry of the International Society for Heart and Lung Transplantation, Kaye MP (personal communication, May 1991).

These data also are plotted in Figure 1, together with the survival data from studies of more than 20 patients cited in Table 1. The survival curve from the registry data is comparable to the individual case series data cited in Table 1. Data from the United States on 374 patients are shown in Table 5. The survival rates are quite similar to the international data.

Figure 1. Actual survival rate of heart-lung transplant patients

Table 5. Kaplan-Meier survival analysis for heart-lung transplantation: US data, January 1981-June 1991

Interval, mo | Survivals | Mortalities | Censored [*] | Survival
0 | 374 | 0 | 0 | 100.00
0.5 | 319 | 55 | 0 | 85.29
1 | 299 | 75 | 0 | 79.95
3 | 249 | 125 | 0 | 66.58
6 | 227 | 142 | 5 | 62.00
12 | 197 | 161 | 16 | 56.69
24 | 133 | 186 | 55 | 48.71
36 | 96 | 195 | 83 | 45.03
60 | 38 | 206 | 130 | 37.39

* Statistical estimation of a parameter, such as the probability of survival, depends on the amount of information available for analysis. In this case, the patients for whom complete data are not available for the latest time interval shown (60 months) are annotated in the "censored" column.

SOURCE: From the Registry of the International Society for Heart and Lung Transplantation, Kaye MP (personal communication, May 1991).

Among the factors examined that affect patient survival rates are the diagnosis and age at the time of surgery. Information addressing this point from RISHLT is shown in Tables 6 and 7 for four of the diseases treated with HLT. As can be seen, patients with congenital heart disease and primary pulmonary hypertension have a worse survival rate at all time periods than do patients with Eisenmenger's syndrome or cystic fibrosis.

Table 6. Heart-lung transplant recipient survival by diagnostic category: Worldwide data

Diagnosis | No. of patients | Survival by year
Diagnosis | No. of patients | 1 Year | 3 Years | 5 Years
Congenital heart disease | 86 | 47.6 | 36.3 | 30.6
Primary pulmonary hypertension | 285 | 55.9 | 44.3 | 36.8
Eisenmenger's syndrome | 182 | 66.8 | 55.8 | 51.26
Cystic fibrosis | 154 | 66.0 | 58.6 | 58.6

SOURCE: From the Registry of the International Society for Heart and Lund Transplantation, Kaye MP (personal communication, May 1991).

Table 7. One-tailed [zeta] statistics [*]for selected differences in percentages of survival rates

Comparison | 1 Year | 3 Years | 5 Years
CHD vs. PPH | 1.36 | 1.34 | 1.08
CHD vs. ES | 2.99 [\|] | 3.00 [\|] | 3.33 [\|]
CHD vs. CF | 2.78 [\|] | 3.41 [\|] | 4.44 [\|]
PPH vs. ES | 2.39 | 2.44 [\|] | 3.16 [\|]
PPH vs. CF | 2.10 [\|\|] | 2.89 [\|] | 2.94 [\|\|]

* Using a one-tailed [zeta] statistic test for difference of percentages, it was found that patients with congenital heart disease (CHD) or primary pulmonary hypertension (PPH) each have a significantly worse survival rate after a heart-lung transplant at 1-, 3-, and 5-year intervals than those having Eisenmenger's syndrome (ES) or cystic fibrosis (CF). However, no significant difference was found between the survival rates of patients having a diagnosis of CHD vs. those with PPH.

| The critical value for a one-tailed z statistic at the. 01 level of significance is approximately 2.395.

|| The critical value for a one-tailed z statistic at the .05 level of significance is approximately 1.645.

Tables 8 and 9 show data from two sources that demonstrate the relationship between the age of the patient at the time of HLT and the survival rates al 1, 3, and 5 years. The data indicate that age has very little influence on survival rates.

Other patient characteristics may affect survival rates in patients undergoing HLT. Because sufficient data are not yet available for HLT, the information regarding HT may be the best available surrogate data by which to examine such patient characteristics; HT and HLT share many medical, technical, and logistic features.

Table 8. Heart-lung transplant recipient survival related to age: Worldwide data

Age, y | No. of patients | Survival by year
Age, y | No. of patients | 1 Year | 3 Years | 5 Years
0-9 | 59 | 57.7 | 40.6 | 37.3
10-19 | 146 | 62.2 | 51.5 | 44.4
20-29 | 266 | 61.4 | 51.9 | 44.8
30-39 | 254 | 59.3 | 48.9 | 41.9
40-49 | 180 | 54.0 | 43.8 | 36.2
50-59 | 53 | 55.5 | 43.5 | NA

SOURCE: From the Registry of the International Society for Heart and Lung Transplantation, Kaye MP (personal communication, May 1991).

Abbreviation: NA = Not available.

Table 9. Heart-lung transplants from October 1, 1987-December 31, 1989: 6-month and 1-year patient survival rates by age

Age, y | N | 6-Month survival rate, | SE | 1-Year survival rate, | SE
0-5 | 3 | 100.0 | 0.0 | 66.7 | 27.2
6-19 | 21 | 90.0 | 6.7 | 57.1 | 10.8
20-44 | 103 | 79.8 | 3.9 | 51.5 | 4.9
45-64 | 21 | 72.7 | 9.5 | 52.4 | 10.9
NR | 1 | 100.0 | 0.0 | 100.0 | 0.0

SOURCE: From the 1990 Annual Report of the US Scientific Registry for Organ Transplantation and the Organ Procurement and Transplantation Network.(39)

Abbreviation: NR = not reported; SE = standard error.

The Battelle-Seattle Research HT study, The Center Effect in Heart Transplantations, (40). was based on data collected by UNOS, the International Society for Heart and Lung Transplantation, the Battelle-Seattle Research Center, HCFA, and the American Hospital Association. This analysis, based on transplants performed in 1988, was from data received from 106 of the 117 transplant programs contacted (in which 1,602 transplants were performed). This figure represented 97.3 of all transplants performed worldwide in 1988. The effects of certain patient variables are shown in Table 10. The use of life-support systems, artificial hearts, or other assist devices, as well as retransplantation, had significant adverse effects on 1-year survival rates. Survival was positively affected by the use of triple or quadruple immunosuppressive protocols. Differences in age, sex, and diagnosis had no effect on 1-year survival rates.

Table 10. Actual 1-year heart transplant patient survival rates according to selected variables: Worldwide data, 1988

Characteristic by category | | 1-Year survival rate,
Recipient characteristic | | 1-Year survival rate,
Sex | - Male; - Female | - 82.5; - 82.0
Race | - White; - African American; - Other | - 82.5; - 79.7; - 86.3
Age | - <=15 y; - 16-54 y; - >=55 y | - 77.9; - 83.0; - 82.2
Clinical characteristics
Diagnosis | - Cardiomyopathy; - Coronary artery disease; - Congenital heart disease; - Valvular heart disease; - Other | - 84.9; - 81.1; - 75.5; - 86.5; - 75.2
Patient status prior to transplant | - Receiving life support; - In intensive care, not receiving life support; - Hospitalized, not in intensive care; - Homebound; - Not hospitalized or homebound | - 76.7 [*]; - 83.0; - 82.6; - 84.0; - 88.0
Artificial heart or assist devices | - Yes; - No | - 63.9 [*]; - 83.3
Immunologic characteristics
Immunosuppressive protocol | - CSA + PRED + AZA only; - CSA + PRED + AZA + OKT3 [\|];; - CSA + PRED + AZA + ATG | - 83.6; - 82.3; - 85.1

* These survival rates are significantly lower than other rates in the particular group.

| An antibody to T lymphocyte.

SOURCE: From Reference 40. Abbreviations: ATG = antithymocyte globulin; AZA = ayathioprine; CSA = cyclosporine A; PRED = prednisone.

### Institutional Factors

At the present time, there are few data available that specifically address guidelines and criteria for institutions performing HLT. However, HT was performed earlier than HLT, and guidelines and criteria for institutions performing HT began to evolve in the early to mid-1980s. Since virtually the same institutions performing HT also have been leaders in the development of HLT, these standards and guidelines are useful as an initial model. In 1986, the Task Force on Organ Transplantation of the US Department of Health and Human Services developed criteria for cardiac transplantation centers which included many aspects of institutional organization and function. These include:

- Methods and criteria for the selection of patients.
- Patient management plans.
- Commitment of resources, including those in the areas of cardiology, surgery, anesthesiology, immunology, infectious disease, pulmonary disease, pathology, blood banking, radiology, nursing, and social services. Individuals must be identified in these areas, and the responsible medical/surgical members must be board-certified or eligible or must have demonstrated transplantation competence. The various members of the team must be organized and integrated into a stable, functioning unit.
- Facility plans that include commitment of resources that will ensure a reasonable concentration of experience.

These requirements then were used to determine which institutions were to be certified for Medicare coverage of HT, and the resulting rules were published in April 1987 in the Federal Register.(11). In brief, they comprise several categories that must be addressed by each center submitting an application. These include patient selection and management, commitment, facility plans (plans to perform 12 or more cardiac transplantations per year), experience, and survival rates. A facility must have an established program with documented evidence of 12 or more transplants in each of the two preceding 12-month periods and 12 patients prior to that, since January 1, 1982. Thus, for approval, an institution must have performed 36 HTs. The facility also must demonstrate actuarial survival rates of 73 for 1 year and 65 for 2 years for transplants performed since January 1, 1982. The number of cases required were chosen, in part, because they were large enough to determine statistically meaningful survival outcomes.

Before considering the number of HLTs to be performed as an institutional criterion, it is pertinent to consider the general subject of the number of surgical procedures performed and patient outcomes. A number of studies support the notion that there is a positive relationship between the number of a particular type of surgical procedure performed at an institution and better patient outcomes.(41,42). This effect was seen in some types of surgical procedures but not in others, and, in general, this positive relationship was more often observed in more complex surgical procedures. There are several alternative explanations for such a relationship. First, it is possible that patient selection factors and different mixes of patients in different types of institutions are the cause of the observed effect. The second explanation is that, indeed, "practice makes perfect," and institution with higher volumes and greater experience with particular procedures learn by doing and thus have better results. The third explanation is that the observed positive relationship is due to the fact that hospitals with more skillful surgeons and operating and recovery room teams are known to provide superior outcomes and thus may attract more patients suffering from a particular condition. In this context, larger surgical volumes in particular institutions are due to referral patterns that lead to more patients being sent to institutions that have better results. An analysis of the second and third hypotheses concluded that, for different surgical procedures and medical conditions, one or the other of these explanations may be more important.(43) The studies, however, did not directly examine these relationships with regard to HT or HLT.

With regard to organ transplantation in general, the Battelle-Seattle Research Center recently published a comprehensive report, The Concept of Center Effect in Organ Transplantation.(44) This study concluded, in part, that there is little evidence, based on published reports, that the volume of procedures performed has a beneficial impact on the outcomes of transplantation. However, this report did not specifically address HT.

New data concerning institutional criteria for HT now are available and can be used to evaluate the outcome probability relating to the volume and several other criteria of HT centers. Since too few HLT procedures have been performed at most institutions to allow for reliable statistical analyses, the information regarding HT may be the best available surrogate data by which to establish initial institutional criteria for HLT.

The Battelle-Seattle study of HT has been cited in regard to certain patient characteristics.(40) This analysis showed considerable variation of patient survival rates at different centers. For example, in the institutions examined, 10 centers had 1-year survival rates of 50 or less, 67 had 1-year survival rates greater than 80, and 32 reported 1-year survival rates greater than 95. A complex array of factors may contribute to such differences in survival rates among institutions. The study assessed the source of this variation both in terms of differences in the patient mix (age, race, sex, and diagnosis prior to transplant) across centers and differences among the centers themselves. More particularly, this study addressed such transplant center variables as cardiologist experience, surgeon experience, and program volume. When these factors were analyzed in four multivariate models, the following was observed: In the first model, a program volume of less than 12 had an adverse effect on patient survival. In the second model, when surgeon experience equaled or exceeded 50 transplants, there was a modest, positive effect on survival. In a third model, Medicare approval in 1988 or earlier had a positive effect on patient survival, suggesting that Medicare institutional criteria were valid.

It should be noted that some of these data were obtained after the HCFA institutional recommendations had already been put into effect, and it is possible that implementation of these recommendations may have had a positive effect on outcomes. In summary, the data in this report give some support to a hypothesis that there is a positive correlation between the number of HTs performed at an institution and surgeon experience and the 1-year survival rate of HT patients.(40) While this study included a large sample of more than 1,600 patients, these observations were limited to a single year (1988), and extrapolation beyond these data is problematic. Another such analysis of institutional influences on the outcomes of HT is now available.(45) Information for this study was obtained from RISHLT and a survey of 56 HT centers in the United States. The results were based on an analysis of 1,123 recipients who received HTs between 1984 and 1986.

Several institutional variables affecting the 90-day postoperative survival rate were considered. The correlation between outcome and previous HT experience by the members of the transplant team (i.e., cardiologist, transplant coordinator, and surgeon) was assessed, and it was found that previous experience of both the cardiologist and the coordinator played a major role. The risk of mortality was increased by factors of 2.7 and 2.0, respectively, when these individuals lacked prior experience. However, no correlation was found between surgeon HT experience and outcome.

Second, a number of variables related to the "learning curve" phenomenon were found to be significant. The mortality rate for the first five patients receiving transplants in an institution was significantly higher than that of subsequent patients (19.8 compared with 11). This finding not attributable to differences in patient selection. In addition, experience in HT on low-risk patients was found to be transferable to high-risk patients, since the mortality of a high-risk patient was inversely related to the number of low-risk patients previously operated on in that institution. A high transplant rate in startup centers was positively correlated with a favorable outcome but did not reach a level of statistical significance. The authors noted that there was an inverse relation between transplant program duration and mortality. Older transplant centers, without exception, have lower mortality rates than newer ones. This difference could not be explained by the differences in patient selection in the various centers.

However, despite the fact that the 56 HT centers exhibited marked heterogeneity in total volume (1 to 207) and in mortality (0 to 75), there was no correlation between these variables (r = -.03).

Finally, another factor that may have influenced HT outcomes during the time of the above study is the use of triple-drug therapy (cyclosporine, prednisone, and azathioprine). In the years between 1984 and 1986, use of triple-drug immunosuppressive therapy grew rapidly and could conceivably have been a factor resulting in the more favorable outcomes in the latter part of this study. Patients not receiving triple-drug therapy had a relative risk of 2.0 compared with patients receiving such therapy. This same beneficial effect of triple immunosuppressive therapy on survival also was seen in the Battelle-Seattle analysis.(40)

In summary, the Battelle-Seattle study(40). and the Laffel study(45). showed somewhat different results. In the Battelle-Seattle study, low program volumes had an adverse effect on patient survival, and surgeon experience had a positive effect on outcomes. However, in the Laffel study, this latter effect was not observed; rather, the degree of experience of the transplant coordinator and the cardiologist had a positive effect on patient outcomes, as did the duration of the transplant program. The Laffel study observed no correlation between overall program volume and patient outcomes. However, the authors did note an inverse relationship between cumulative experience with HT and postoperative mortality. It would, therefore, appear that a complex mix of factors affects survival outcomes.

Information about HLT, although not as extensive as that about HT, is also available from the UNOS Report of the US Scientific Registry for Organ Transplantation.(6). A total of 150 HLTs were performed at 37 institutions in the United States between October 1, 1987, and December 31, 1989. Nineteen of these institutions performed only one or two Figure 2 shows the relationship between the number of HLTs performed and 1-year survival rates. As can be seen, programs performing a small number of transplants have greater variability in survival rates than do programs performing more transplants. Thus, survival rates in institutions with low patient volumes are not very meaningful. Twenty of these 37 institutions also performed HT and LT; the number of all three procedures performed per institution during that 27-month period ranged from 5 to 160 with a mean of 46. However, only three of the 37 institutions did more than 10 HLTs. As previously discussed, the number of particular procedures performed at a given center must be considered a significant factor in proposing institutional criteria. Thus, since the number of HLTs performed at individual institutions is often low, a combined figure including HLT, HT, and LT should logically be used as a basis for institutional review. The inclusion of HT and LT is based on the fact that many of the technical, surgical, patient-supportive, and logistic elements are shared among these three procedures.

Figure 2. Number of heart-lung transplants performed and 1-year survival

Finally, limited evidence as to whether setting specific institutional standards can affect HT patient outcome is available from Medicare experience with HTs performed between August 1, 1987, and December 31, 1991. A total of 5,553 HTs were performed in Medicare-approved hospitals, and 2,332 Hts were performed in non-Medicare-approved hospitals. Life-table analysis of survival in Medicare-approved hospitals was 83. 8 +/- 0.7 at 1 year and 76.7 +/-0.7 at 3 years; the survival in non-Medicare-approved hospitals was 80.7 +/-0.6 at 1 year and 72.5 +/-0.7 at 3 years. The p value for this difference, .001, is statistically significant (Shekar S and Krakauer H, Health Care Financing Administration; personal communication, August 1992). Thus, Medicare approval is associated with a small but statistically significant improvement in 1-to 3-year survival after HT.

## Consultations

As part of the assessment process, other agencies of the Public Health Service were consulted. NIH provided the following information.

### Patient Criteria

Lung and heart-lung transplantations have been done in patients with irreversible, progressively disabling end-stage lung disease (or heart and lung disease) with survival expected to be less than 12 to 18 months or less than 1 or 2 years. For each patient, this is the professional judgment of an experienced physician. It must be based on thorough clinical and physiologic assessment of the patients and observation of responses to medical therapy and attempts at rehabilitation.

In brief, both LT and HLT in carefully selected patients and by experienced teams yield significant increases in survival with reasonable quality of life and at costs that are not out of the range for other expensive therapies. However, at present, HLT is used less commonly and primarily in situations in which there is coexistence of end-stage pulmonary disease with advanced cardiac disease that is not secondary to pulmonary hypertension.

Affirmative criteria include:

- The patient must have irreversible, progressively disabling, end-stage pulmonary or cardiopulmonary disease (e.g., less than a 50 likelihood of survival for 8 months). Prognosis otherwise must be good both for survival and rehabilitation.
- All other medical and surgical therapies that might be expected to yield both short-and long-term survival comparable to that of transplantation must have been tried or considered.
- The patient must have a realistic understanding of the range of clinical outcomes that may be encountered.
- Plans for long-term adherence to a disciplined medical regimen must be feasible and realistic for the individual patient.

Many factors must be recognized as exerting an adverse influence on the outcome after transplantation. A patient who meets the above criteria and is free of the adverse factors cited on tne next page is considered a good candidate for transplantation.

Some of the factors cited below have important qualifications. It is recognized that some patients who may not be considered "good candidates" might also benefit from transplantation, but the likelihood or extent of benefit is thought to be significantly less.

Adverse criteria include:

- Acute illness (i.e., serious exacerbation of chronic end-stage disease or with nonchronic end-stage disease) or current requirement of mechanical ventilation for more than a very brief period (because there is difficulty in adequate assessment, a propensity for infection, and likelihood of poor results).
- Significant systemic or multisystem disease.
- Extrapulmonary site of infection (because of the probability of recrudescence once immunosuppression is instituted).
- Hepatic dysfunction, even secondary to right ventricular failure.
- Renal dysfunction, such as a preoperative serum creatinine greater than 1.5 mg-dL or a 24-hour creatinine level clearance less than 50 mL/min.
- Systemic hypertension that requires multidrug therapy for even moderate control.
- Cachexia, even in the absence of major end-organ failure (because of the significantly less favorable survival of these patients).
- Obesity, with weight being an increasingly severe adverse factor as the patient's weight exceeds 20 over the ideal weight for height and sex.
- A history of a behavior pattern or psychiatric illness considered likely to interfere significantly with compliance with a disciplined medical regimen.
- Continued cigarette smoking or failure to have abstained for a long enough time (at least 1 or 2 years) to indicate low likelihood of recidivism.
- Previous thoracic or cardiac surgery or other bases fro pleural adhesions that may be serious adverse factors depending on the site of thoracotomy/stermotomy.
- Age beyond 50 or 55 (an increasingly severe adverse factor).
- Recent or current history of gastrointestinal problems (because of common postoperative gastrointestinal problems and hemorrhage).
- Chronic corticosteroid therapy that cannot be tapered to a low dose and/or discontinued prior to transplantation. This has been considered a serious adverse factor by many because of the increased risk of tracheal or bronchial dehiscence in the early postoperative period.

### Institutional and Team Experience

Institutional and team experience should be based on all LTs and HLTs performed since a given date that are at least 4 years prior to the date at which experience and survival are reported.

To be accepted for LT (i.e., both single and double lung), an institution and team should have:

Performed LT and/or HLT in at least 10 patients within the 12 months prior to application and in at least an additional 10 patients prior thereto, and achieved a documented Kaplan-Meier actuarial survival rate of no less than 65 at 1 year.

To be accepted for performance of HLT, an institution and team should:

Fulfill the above criteria for LT and the existing HCFA and Civilian Health and Medical Program of the Uniformed Services (CHAMPUS) criteria for HT. Thus, to perform HLTs, the institution and team would have to fulfill the criteria for both HT and LT.

Another NIH institute indicated that an important risk factor for HLT would be the presence of human leukocyte antigen (HLA) antibodies in the recipient. If these antibodies are present, it is likely that these transplanted organs might suffer hyper-acute rejection. They also stated that in HT recipients with HLA antibodies, there is a poorer 5-year survival rate and an increased incidence of coronary artery disease.

In response to the Federal Register notice of this assessment and solicitation of information and opinion from individuals and groups having experience with HLT, OHTA has received a number of comments (one of which will be cited in detail). The responses of these groups are summarized in Tables 11 and 12.

HRSA forwarded OHTA's request to the Thoracic Organ Transplantation Committee of OPTN. This committee provided the response cited below.

In general, the surgical principles for HLT are similar, although somewhat more complex, than those for HT. The basic immunosuppressive protocol and the approach to patient care should be essentially identical to that of cardiac transplant patients with the single exception that close surveillance of the lungs for possible rejection is critically important.

Medical indications for which HLT is performed include end-stage Eisenmenger's syndrome and primary pulmonary hypertension. Less common indications for HLT include cystic fibrosis with end-stage pulmonary failure and combined end-stage disease of both the heart and lungs.

The same general contraindications to HT also apply to HLT. Patients also are at particularly high risk during HLT if they have had previous major thoracic or mediastinal operations, due to the likelihood of excessive bleeding at the time of transplantation.

Institutional requirements for HLT are generally the same as those for HT. Specifically, a team that is qualified through experience and survival in HT is coupled with appropriate personnel. If the institution has been approved for CHAMPUS coverage of HT, then that institution also should be covered for HLT (if they have performed three or more HLTs with a 60 1-year survival). Given the appropriate degree of surgical expertise, HLT is a natural extension of HT in a highly successful and experienced HT program. HRSA stated that the information provided by this committee represents the opinion of its members and that OPTN and HRSA do not have an official opinion on this matter.

The commentary received from several transplant centers (Table 11) regarding institutional criteria varied; e.g., the minimally suggested 1-year survival rates for HLT procedures ranged from 50 to 70. The number of HLT procedures considered necessary per institution ranged from 2 or 3 to 10 per year, or to a total of 25 HLTs. NIH, in this regard, recommended that an institution should have performed 20 HLTs or LTs and also fulfilled the existing HCFA and CHAMPUS criteria for HT. NIH, however, did not make a specific recommendation for the number of HLTs to be performed over a specific period of time. The total recommended NIH requirements therefore would be a total of 56 procedures (including HLT, HT, and LT) over a 3-year period. The ability of an institution to fulfill these requirements appears problematic, since only 15 of the 37 institutions performed more than 52 procedures (HLT, HT, and LT) in 37 months. Four institutions indicated that current CHAMPUS HT criteria also should apply to HLT; however, one institution indicated that this was inappropriate. Furthermore, another institution recommended that HLT should be performed only in a very limited number of institutions.

Table 11. Summary of correspondence received from institutions regarding heart-lung transplantation

Correspondent | Institution | Patient criteria | Institutional criteria
Cooper | Washington University School of Medicine, St Louis, MO | Irreversible cardiopulmonary disease. | Establish 4-6 centers to maximize expertise.
McGregor | Mayo Clinic, Rochester, MN | Irreversible PHT and irreversible heart disease, CF. | 60 1-y survival rate, no. of procedures not important.
Griffith | University of Pittsburgh, Pittsburgh, PA | Indicated in:; - Irreversible congenital heart disease with PHT.; - Parenchymal pulmonary disease with severe RV failure. | Minimum 25 HLTs (total). 50 1-y survival rate. Current CHAMPUS criteria for HT generally appropriate, but needs pulmonary disease experience.
Griffith | University of Pittsburgh, Pittsburgh, PA | Contraindicated when:; - HT contraindicated.; - Unwilling to receive blood.; - HIV antibody-positive.; - Extensive prior chest surgery. | Minimum 25 HLTs (total). 50 1-y survival rate. Current CHAMPUS criteria for HT generally appropriate, but needs pulmonary disease experience.
Kapelanski | University of Iowa, Iowa City, IA | - Idiopathic PHT.; - Eisenmenger's complex.; - Congenital cardiac disease with atresia of pulmonary circulation.; - Emphysema.; - CF. | Current UNOS and CHAMPUS HT criteria appropriate, with additional pulmonary expertise.
Smith | University of California, San Diego, CA | - Primary PHT.; - Eisenmenger's complex.; - CF.; - PHT with irreversible cardiac disease (NYHA Class III/IV).; - Bronchiectasis.; - Age <45y. | 10 LTs HLTs per year, 70 1-y survival rate, 55 2-y survival rate. Program should be in existence for 2 y; current CHAMPUS criteria not appropriate.
Dresdale | Henry Ford Hospital, Detroit, MI | - Irreversible cardiac and pulmonary disease such as Eisenmenger's complex.; - Age<50y. | Perform a significant number of HTs with acceptable mortality.
Burton | Virginia Heart Surgery Associates, Fairfax, VA | - Irreversible cardiopulmonary disease, PHT.; - No alternative treatment.; - <18 mo life expectancy.; - NYHA class III/IV.; - Age<50y.; - No other significant disease.; - Psychologically stable, with adequate family support.; - No substance abuse or dependence. | - 80 1-y survival rate for HT.; - "Sufficient" volume.; - "Authorization" from UNOS.; - 60 1-y survival rate for HLT.; - In an active HT center, 2-3 HLTs annually.
Starnes | Stanford University School of Medicine, Palo Alto, CA | Pulmonary vascular diseases:; - Primary pulmonary hypertension.; - Eisenmenger's syndrome.; - PHT secondary to thromboembolic disease.; - Cardiomyopathy with PHT.; - Obstructive lung diseases:; - Emphysema -idiopathic.; - Emphysema -[alpha](1) antitrypsin deficiency.; - CF.; - Bronchiectasis.; - Bronchopulmonary dysplasia.; - Posttransplant obliterative bronchiolitis.; - Restrictive lung diseases:; - Idiopathic pulmonary fibrosis.; - Sarcoidosis.; - Asbestosis.; - Histiocytosis X.; - Bronchiolitis obliterans; organized pneumonia.; - Desquamative interstitial pneumonitis.; - Lymphangioleiomyomatosis. | NS
Baumgartner | Johns Hopkins University School of Medicine, Baltimore, MD | - Age <60 y.; - Poor prognosis for 1-y survival.; - No other life-threatening systemic disease.; - Previous demonstration of absolute compliance with medications and medical recommendations.; - Emotional stability and must have a realistic understanding of the implication of organ transplantation.; - Strong supportive family constellation that is able and willing to tolerate the family upheaval and stresses of cardiac transplantation.; - Adequate financial resources. | NS

Recommendations regarding patient criteria also varied; the maximum age believed appropriate for HLT ranged from 45 to 60 years. There was general agreement that patients with irreversible cardiopulmonary disease are candidates for HLT. Among the diseases mentioned were pulmonary hypertension with congestive heart failure, cystic fibrosis, emphysema, bronchiectasis, and restrictive lung disease. Thus, there was a considerable range of opinion from responding institutions with regard to institutional criteria, and patient selection criteria were phrased only in general terms.

In response to the Federal Register notice of this assessment, the American College of Cardiology (ACC) also provided comment. The ACC indicated that many patients who were previously considered candidates for HLT are now more appropriately treated with LT. The advantages to individual patients, as well as advantages on a more general level due to the expanded supply of donor organs when hearts and lungs are used separately, are widely accepted concepts in the transplant community.

The ACC believes that absolute contraindications for HLT include:

- Active extrapulmonary infection.
- Other irreversible organ dysfunction, e.g., hepatic or renal failure.
- Malignancy (other than basal skin carcinoma) unless thought to be "cured. "
- HIV seropositivity.
- Previous thoracotomy involving pleurectomy or pleurodesis.
- Insulin-dependent diabetes with end-organ damage.

The ACC concluded that specific indications for appropriate cardiopulmonary (heart-lung or lung) transplantations are end-stage cardiopulmonary disease that cannot be treated by other types of medical or surgical management, and/or severe primary lung disease with only mild or absent right ventricular dysfunction. Patients to be considered for HLT should include:

- Patients with congenital cardiac abnormalities associated with severe pulmonary hypertension (Eisenmenger's complex).
- Patients with untreatable primary lung disease associated with severe secondary right-heart failure.
- Patients with cardiomyopathy associated with irreversible secondary pulmonary hypertension.

The ACC recommended that transplant team criteria should be similar to those already established for cardiac transplantation and should include the availability of a team of physicians, surgeons, nurses, social workers, and psychologists approved for cardiac transplantation. In addition, a separate group of pulmonary medicine specialists and surgeons with specialty training in thoracic surgery should be part of the team. A group of perfusionists capable of performing extracorporeal membrane oxygenation as well as prolonged left-and right-heart assist should be available as well. The physician team should include a minimum of two cardiothoracic surgeons, two transplant physicians, and one pulmonary medicine specialist. Institutional availability of expert consultation in the fields of infectious diseases, immunology, and nephrology should be the same as that required for cardiac transplantation. Such a center should be UNOS-and Medicare-approved for cardiac transplantation.

The ACC believes that existing CHAMPUS heart transplantation institutional and team criteria are appropriate for HLT and should be implemented as far as the team qualifications are concerned.

A brief summary of expert opinion taken from the published literature regarding contraindications to HLT is shown in Table 12.

Table 12. Contraindications for heart-lung transplantation

Factor | Organizations | | | Published literature
Factor | National Institutes of Health | American College of Cardiology | Thoracic Organ Transplant Committee of OPTN | Ref. 33 (opinion survey) | Ref. 12-32 and Starnes [*]
Significant renal disease, CrCl <50 mL/min | X | X | All contraindications "same as heart transplants" | X | X
Current steroid therapy | X | | | X | X
Smoking | X | | | X | X
Drug/alcohol abuse | | | | X | X
HIV seropositivity | | X | | X | X
Hepatic disease and/or hyperbilirubinemia >3.5 mg/100mL | | X | | | X
Psychiatric illness | X | | | | X
Previous chest surgery | X | X | X
Age over: | 55 | | | 60 | 55
Poor family support structure | | | | | X
Cachexia or obesity | X | | | | X
Systemic/multisystem disease not otherwise specified | X | | | | X
Infection - pulmonary or extrapulmonary | X | | | | X
CVA with significant residual impairment | | | | X
Down's syndrome | | | | X
Presence of malignancy | | Any cancer unless "cured" | | X
Recurrent pulmonary emboli | | | | X
History of noncompliance | X
Hypertension on multidrug therapy | X
Acutely ill or ventilator-dependent | X
Recent/current gastrointestinal problems | X
Insulin-dependent diabetes with end-organ damage | | X

* Starnes VA, Stanford University (personal communication, August 1990).

## Discussion

The criteria for patient selection reported in the medical literature, provided by expert opinion, and provided to OHTA by individual institutions, were framed in varying degrees of detail and threshold and often in very general terms. Moreover, the criteria often differed and it was not evident that they were based on objective data. For example, in the case of maximum age for HLT, opinion ranged from 45 to 60 years. However, the data in Tables 8 and 9 demonstrate that there is no significant difference in survival following HLT in patients ranging in age from less than 1 to 64 years. While there appears to be nearly universal opinion that candidates for HLT should have progressive end-stage disease of the heart and lungs not amendable to medical therapy and with a life expectancy of only 8 to 12 months, it is difficult to extract specific patient criteria from various published series of HLTs. In general, however, the procedure was initially used in those patients for whom the likelihood of benefit was greatest (e.g., those with a poor prognosis and minimal comorbidity). Moreover, the general literature does not provide sufficient numbers of patients to derive a reliable relationship between particular preoperative diagnoses and the outcomes of HLT. However, the data provided by RISHLT (Tables 6 and 7). demonstrate that patients with cystic fibrosis and Eisenmenger's syndrome have better outcomes than do patients with congenital heart disease and primary pulmonary hypertension.

Certain variables have been shown to affect outcomes of HT.(40) Patients using life-support systems (such as ventricular assist devices or artificial hearts) and those receiving a second HT have poorer outcomes. It is likely that the same effects will be observed in patients having HLT.

Expert opinion submitted to OHTA was heterogeneous and varied in detail and threshold with respect to patient selection ( Tables 11 and 12). Consequently, it seems reasonable that, at present, the criteria suggested by NIH, a source that is both credible and impartial, form the basis for patient selection. Individual transplant centers that advance differing criteria should provide a compelling rationale for such proposals.

The objective of establishing institutional criteria is to reduce risk and improve outcomes of HLT while not unreasonably limiting the number of transplant centers and patient access. An important parameter with regard to institutional selection criteria is patient survival rates. Data for HLT survival rates in the United States are available from RISHLT. The overall survival rates (for 374 patients) are 56.7 at 1 year, 48.7 at 2 years, and 45 at 3 years. The 1-year survival rates plotted against program volume for 37 United States institutions performing HLT are contained in Figure 2. There appears to be no discernible relationship between survival rates and program volume; however, the fact that many institutions only performed one or two transplants makes this relationship tenuous. The reliability of data from such small-volume programs is uncertain (because as sample size becomes smaller, the error of statistical estimates becomes larger). Furthermore, the numbers of HLTs performed at one individual institution are too few to calculate meaningful survival rates; survival rates for HT and LT performed at the same institution also would have to be considered as components for institutional acceptability.

In the absence of reliable data regarding the effect of program volume, the experience requirements provided by NIH may be a rational alternative. It seems reasonable that institutions performing HLT should be subject to the same facility requirements as those mandated by HCFA and CHAMPUS for HT and, in addition, should have surgeons, cardiologists, and transplant coordinators with previous HLT experience. Furthermore, institutions performing HLT must have pulmonary disease expertise, proven experience in the technique of transbronchial lung biopsy, pathologic diagnosis, and management of pulmonary rejection episodes. Also, physicians with transplant-recipient experience should be available. Panels of experts in these areas may be used to provide probationary approval of centers with a final approval made after sufficient data regarding each institution have become available.

Expected changes in surgical techniques, methods of immunosuppression, and resultant improved survival should prompt ongoing reevaluations of both patient and institutional criteria for HLT (as sufficient data become available). Indeed, HLT is becoming less frequently performed because single lung transplants are considered by many to be more efficacious in certain circumstances.(38)

## Summary and Conclusions

Heart-lung transplantation is a complex, expensive, and resource-intensive procedure. It is performed more often where there is coexistence of end-stage pulmonary disease with advanced cardiac disease that is not secondary to pulmonary hypertension (e. g., some forms of congenital heart disease, some situations with Eisenmenger's syndrome, and possibly the coexistence of end-stage heart and end-stage lung disease). Available data indicate that some disease states are associated with a higher probability of successful outcome after HLT than are others.

Objectively validated and reliable patient selection criteria cannot be obtained from the current medical literature. Expert opinion provided to OHTA contained varying degrees of detail and uniformity with respect to patient selection (Tables 11 and 12). While most agree that "irreversible cardiopulmonary disease" is an indication for this procedure, there are no published data that have provided details as to how patients so designated were selected as candidates for HLT. For example, for chronic obstructive pulmonary disease (emphysema), neither expert opinion nor published studies of HLT provided data indicating the stage of the disease at which a decision to transplant is reasonable and objectively justifiable. A similar lack of detail for cystic fibrosis, bronchiectasis, pulmonary fibrosis, sarcoidosis, asbestosis, and other diseases was noted. Thus, there are insufficient data regarding transplant recipients to permit the development of objective criteria for a threshold for HLT in the various disease states.

The circumstances are more problematic regarding suggested contraindications for HLT. While objective survival rates obtained from registry data indicated that survival bore little relationship to recipient age, various opinions provided to OHTA specified a maximum age for HLT candidates, ranging from under 45 years to 60 years. Adverse factors and contraindications, such as "other significant disease," "recurrent pulmonary emboli," "hepatic disease," "infection," and "insulin-dependent diabetes" were nonspecific and unsupported by published, objective evidence. More ambiguous contraindications included "psychiatric illness," "poor family support structure," "history of noncompliance with medical regimens," and lack of "emotional stability." While psychiatric , psychologic, or sociologic evaluations of potential HLT recipients undeniably have relevance to patient selection, use of such criteria should be supported at least by evidence of generally consistent application across the transplant community. Of note was the recommended requirement that the recipient possess "adequate financial resources," which implies that the benefits of HLT are not expected to be equitably provided to the public. This precondition, while perhaps considered both rational and practical on the part of individual institutions, contradicts the principle of distributive justice clearly enunciated in the Belmont Commission's report to the Federal Government.(46) Since donated organs as well as the system of distribution of those organs are considered to be a public resource, this contradiction is troublesome.

NIH has provided detailed recommendations regarding patient selection; it is not unreasonable to accept the NIH criteria until such time as objective evidence is available as a basis for revision. Transplant centers that perform HLT should endeavor to that end, to compile and report data that would permit the derivation of patient selection criteria on an objective basis.

Institutional selection criteria are predicated to allow for the formulation of program elements which minimize the risk-benefit ratio, provide for improved patient outcomes, and permit, insofar as possible, access to transplantation technologies. Opinion provided to OHTA regarding institutional selection criteria represented a spectrum of beliefs (Table 11). One-year survival rates of 50 to 70 for HLT were specified, but, as previously noted, survival rates of low-volume programs may have little meaning. The establishment of a small number of centers (4 to 6) to maximize expertise also was advocated, but it is unclear that a selection process that would so limit access would be objectively defensible by available data.

Correspondents' opinions differed as to whether or not current Medicare and CHAMPUS criteria for HT were appropriate for HLT as well. Again, in the face of limited data, the recommendations preferred by NIH appear to constitute rational, initial institutional selection criteria. However, it is not clear precisely how many centers currently performing HLT would meet the NIH program volume and combined HLT/LT one-year survival requirements. Specifically, 37 institutions performed HLT between 1987 and 1989, but only 19 of these also performed both HT and LT.(6) NIH recommended a 65 one-year actuarial survival requirement for combined LT/HLT cases. This must be considered in view of transplant registry data, which reveal that the mean national one-year survival rates for HLT and LT are 56.7 (n =374) (10). and 54 (n =127), (7). respectively.

Institutions performing HLT should already have complete and committed facilities for performing HT, and they should have, in addition, experts in pulmonary diseases and pulmonary physiology, demonstrated ability to do transbronchial biopsies, appropriate diagnostic pathology services, And the ability to manage both acute and chronic rejection episodes.

The dearth of evidence severely handicaps attempts to establish logical and scientifically defensible patient and institutional selection criteria for HLT. Careful compilation of information is necessary to permit further refinement of such criteria, and the responsibility for provision of this information properly resides within the transplant community.

## References

1 Bonser RS, Jamieson SW. Heart-lung transplantation Clim Chest Med 1990 11:235 246
2 Reitz BA. The history of heart-lung transplantation in Baumgartner Wa, Reitz Ba, Achuff SG (Eds): Heart and Heart-Lung Transplantation, Philadelphia: WB Saunders Co. 1990 pp 1 11
3 Stanes Starnes VA. Heart-lung transplantation: An overview Cardiol Clin 1990 8:159 168 2407357
4 Shumway SJ. Basic immunological concepts involved in organ transplantation in Baumgarter WA, Reitz BA, Achuff SG (Eds): Heart and Heart-Lung Transplantation. , Philadelphia: WB Saunders Co., 1990, pp 15 21
5 Reitz BA, Wallwork JL, Hunt SA, et al. Heart-lung transplantation N Engl J Med 1982 306:557 564
6 US Department of Health and Human Services. Annual Report of the US Scientific Registry for Organ Transplantation 1991 Health Resourcs Resources and Services Administration, Division of Organ Transplantation, Rockville, MD.
7 [no authors listed] US Department of Health and Human Services, Public Health Service, Health Resources and Services Administration. 1991 Report of Center-Specific Graft and Patient Survival Rates. Executive Summary
8 Brink SD, Hauboldt RH, Cincota KA. Research Report: Cost Implications of Human Organ Transplantations. An Update Milliman and Robertson, Inc.,, Brookfield, WI: 1990
9 Reitz BA. Heart and lung transplantation in Baumgartner WA, Reitz BA, Achuff SG (Eds): Heart and Heart-Lung Transplantation., Philadelphia: WB Saunders Co., 1990 pp 319 346
10 Fraser CD, Tamura F, Kontos GJ, et al. (1988;). Evaluation of current organ preservation methods for heart-lung transplantation. Transplant Proc.
11 [no authors listed] Health Care Financing Administration (HCFA) Federal Register. April 6, 1987 52:10947 10948 10557619
12 McGeorge McGregor CGA, Jamieson SW, Baldwin JFC. Combined heart-lung transplantation for end-stage Eisenmenger's syndrome J Thorac Cardiovasc Surg 1986 91:443 450 3081765
13 Penketh A, Higenbottam T, Hakim M, et al. Heart and lung transplantation in patients with end-stage lung disease Br Med J 1987 295:311 314 3115428
14 Hutter JA, Despins P, Higenbottam T, et al. Heart-lung transplantation: Better use of resources Am J Med 1988 85:4 11
15 Hutter JA, Scott JP, Deespons P, et al. Heart-lung transplantation at Papworth Hospital Eur J Cardiothorac Surg 1989 3:300 304 2624801
16 Kawaguchi A, Gandjbakhch I, Pavie A. Heart and unilateral lung transplantation in patients with end-stage cardiopulmonary disease and previous thoracic operation J Thorac Cardiovasc Surg 1989 98:343 349 2528034
17 Rhenman B, Rhenman MJ, Icenogle TB. Heart-lung transplantation: The initial Arizona experience J Thorac Cardiovasc Surg 1989 98:922 927 2554069
18 Courand Couraud L, Baudet E, Velly JF, et al. Lung and heart-lung transplantation for end-stage lung disease Eur J Cardiothorac Surg 1990 4:318 322 2361020
19 Fradet G, Smyth RL, Scott JP, et al. Cystic fibrosis: A new challenge for cardiothoracic surgery Eur J Cardiothorac Surg 1990; 4:136 141 2334553
20 Yacoub MH, Khaghani A, Miyamura H, et al. Heart-lung transplantations: transplantation—Harefield experience Jpn J Surg 1990 20:247 251 2359202
21 McCarthy PM, Starnes VA, Theodore J. Improved survival after heart-lung transplantation J Thorac Cardiovasc Surg 1990 99:54 60 2294365
22 Khaghan Khaghani A, Banner N, Ozdogan E, et al. Medium-term results of combined heart and lung transplantation for emphysema J Heart Lung Transplant 1991 10:15 21 2007166
23 Whitehead B, Helms P, Goodwin M, et al. Heart-lung transplantation for cystic fibrosis 2: Outcomes Arch Dis Child 1991 66:1022 1026 1929506
24 Starnes VA, Marshall SE, Lewiston NJ, et al. Heart-lung transplantation in infants, children, and adolescents J Pediatr Surg 1991 26:434 438 2056404
25 de Laval M, Smyth R, Whitehead B, et al. Heart-lung transplantation for terminal cystic fibrosis J Thorac Cardiovasc Surg 1991 101:633 642 2008101
26 Madden BP, Hodson ME, Tsang V, et al. Intermediate-term results of heart-lung transplantation for cystic fibrosis Lancet 1922; 1992; 339:1583 1587
27 Jamieson SW, Stinson EB, Oyer PE, et al. Heart-lung transplantation for irreversible pulmonary hypertension Ann Thorac Surg 1984 38:554 562 6439134
28 LeGal YM. Lung and heart-lung transplantation Ann Thorac Surg 1990 49:840 844 2187426
29 Scott J, Higenbottam T. Transplantations Transplantation of the lung lungs and heart and lung for patients with severe pulmonary complications of from sarcoidosis Sarcoidosis 1990 7:9 11 2345828
30 Bonser RS, Fragomeni LS, Jamieson SW. Heart-lung transplantation Invest Radiol 1989 24:310 322 2545649
31 Vouche Vouhe PR, Bidois Le Bidois J, Dartevelle PH, et al. Heart-and heart-lung transplantation in children Eur J Cardiothorac Surg 1989 3:191 195 2624781
32 Baumgartner WA. Organizational aspects of a transplant program in Baumgartner WA, Reitz BA, Achuff SG (Eds): Heart and Heart-Lung Transplantation, Philadelphia: WB Saunders Co., 1990 pp 25 30
33 Morrison DL, Maurer JR, Grossman RF. Pre-operative Preoperative assessment of lung transplantation Clin Chest Med 1990 11:207 215 2189656
34 Blakeman BM, Pifarre R, Sulivan H, et al. High-risk heart surgery in the heart transplant candidate J Heart Transplant 1990 9:468 472 2231085
35 Smyth RL, HiggenbottamHigenbottam TW, Scott JP, et al. Early experience of heart-lung transplantation Arch Dis Child 1989 64:1225 1230 2817941
36 Wallwork J, Williams R, Calyne RY. Transplantation of liver, heart, and lungs for primary biliary cirrhosis and primary pulmonary hypertension Lancet 1987 2:182 184 2885640
37 Evans RW, Manninen DL, Dong FB, et al. Heart-lung transplantation recipient and donor selection criteria: The results of a consensus survey in Evans RW, Manninen DL, Dong FB (Eds): The National Cooperative Transplantation Final Report, Seattle, WA: Battelle-Seattle Research Center, June 1991
38 [no authors listed] Lung transplantation (editorial) Lancet 1992 339:1021 1022
40 Evans RW, Dong FB, Manninen DL. The concept of center effect in heart transplantation in Evans RW, Manninen DL, Dong FB (Eds): The National Cooperative Transplantation Study: Final Report., Seattle, WA: Battelle-Seattle Research Center, June 1991
41 Luft HS. The relation between surgical volume and mortality: An exploration of causal factors and alternative models Med Care 1980 18:940 959 7432019
42 Luft HS, Bumper Bunker JP, Enthoven AC. Should operations be regionalized? The empirical relation between surgical volumes and mortality N Engl J Med 1979 30:1364 1369 503167
43 Luft HS, Hunt SS, Maerki SC. The volume-outcome relationship: Practice makes perfect or selective referral patterns? Health Serv Res 1987 22:157 182 3112042
44 Evans RW. The concept of center effect in organ transplantation in Evans RW, Manninen DL, Dong FB (Eds): The National Cooperative Transplantation Study: Final Report., Seattle, WA: Battelle-Seattle Research Center, June 1991
45 Laffel GL, Barnett AI, Finkelstein S, et al. The relationship relation between experience and outcome in heart transplantation N Engl J Med 1992 327:1220 1225
46 The National Commission for the Protection of Human Subjects of Biomedical and Behavioral Research The Belmont Report: Ethical Principles and Guidelines for the Protection of Human Subjects of Research, Washington, DC: US Government Printing Office, 1988 Publication No. 201-778-180319.