# ^18^F-Labeled 2-Deoxy-2-fluoro-D-glucose Positron-Emission Tomography Scans for the Localization of the Epileptogenic Foci

Health Technology Assessment, Number 12

## Abstract

The localization of epileptogenic foci that are amenable to curative epilepsy surgery may be accomplished by noninvasive surface electroencephalogram (EEG) recordings, clinical observations, computed tomography (CT), magnetic resonance imaging (MRI), and neuropsychologic tests. Other tests, such as invasive EEG, ^18^F-fluoro-deoxyglucose-positron-emission tomography (FDG-PET or PET) scans, and single-photon-emission computed tomography (SPECT) scans, have also been used at various epilepsy centers to help identify candidates who might benefit from such surgery.

Interictal PET scans have demonstrated hypometabolism in areas concordant with the epileptogenic foci indicated by other diagnostic tests such as EEG and MRI. However, PET scans have also shown no abnormality in many patients with EEG-indicated epileptogenic foci; in others, the scans have shown abnormal metabolism in areas that were discordant with the epileptogenic foci. Although substitution of the noninvasive PET scan for the invasive EEG recordings would be desirable, the available data were insufficient to determine whether PET scans might serve as a reliable substitute for EEG. A positive PET scan might contribute independent information for identifying the epileptogenic site but could be noncontributory or confusing when hypometabolism is not seen or is seen in presumably normal brain areas. It is not evident from the data in the literature to what extent confirmatory PET scan findings might contribute to the management of patients with complex partial seizures.

## Foreword

The Center for Practice and Technology Assessment (CPTA) evaluates the risks, benefits, and clinical effectiveness of new or established medical technologies. In most instances, assessments address technologies that are being reviewed for purposes of coverage by federally funded health programs.

The CPTA assessment process includes a comprehensive review of the medical literature and emphasizes broad and open participation from within and outside the Federal Government. A range of expert advice is obtained by widely publicizing the plans for conducting the assessment through publication of an announcement in the Federal Register and solicitation of input from Federal agencies, medical specialty societies, insurers, and manufacturers. The involvement of these experts helps ensure inclusion of the experienced and varying viewpoints needed to round out the data derived from individual scientific studies in the medical literature.

The CPTA analyzed and synthesized data and information received from experts and the scientific literature. The results are reported in this assessment. Each assessment represents a detailed analysis of the risks, clinical effectiveness, and uses of new or unestablished medical technologies. If an assessment has been prepared to form the basis for a coverage decision by a federally financed health care program, it serves as the Public Health Service's recommendation to that program and is disseminated widely.

The CPTA is one component of the Agency for Health Care Policy and Research (AHCPR), Public Health Service, Department of Health and Human Services.

Douglas B. Kamerow, M.D., M.P.H., Director, Center for Practice and Technology Assessment John M. Eisenberg, M.D., Administrator, Agency for Health Care Policy and Research

- Questions regarding this assessment should be directed to:
- Center for Practice and Technology Assessment
- Agency for Health Care Policy and Research
- 6010 Executive Boulevard, Room 316
- Rockville, MD 20852
- Telephone: (301) 594-4026

## Abbreviations

Acc:: Accuracy

ART:: Arrhythmia research technology

BBB:: Bundle branch block

CAD:: Coronary artery disease

CAST:: Cardiac arrhythmia suppression trials

CFR:: Case fatality rate

CHF:: Congestive heart failure

CI:: Confidence interval

CT:: Computed tomography

dQRS:: Duration of the filtered QRS complex > 106 ms

ECG:: Electrocardiogram

EEG:: Electroencephalogram/electroencephalography

FD:: Frequency domain

FDA:: Food and Drug Administration

FDG-PET:: Fluorodeoxyglucose-positron-emission tomography

FU:: Followup

HCFA:: Health Care Financing Administration

IDC:: Idiopathic dilated cardiomyopathy

i-EEG:: Invasive electroencephalography

LAS:: Low amplitude signal

LVEF:: Left ventricular ejection fraction

LVH:: Left ventricular hypertrophy

MeSH:: Medical subject heading

MI:: Myocardial infarction

MRI:: Magnetic resonance imaging

MUGA:: Multigated acquisition

NPV:: Negative predictive value

NS:: Not stated

NSR:: Normal sinus rhythm

NYHA:: New York Heart Association

PES:: Programmed electrical stimulation

PET:: Positron-emission tomography

PPV:: Positive predictive value

RMS:: Root mean square voltage during the last 40 ms of the QRS complex <25 µV

RNV:: Radionuclide ventriculography

SAEGG:: Signal-averaged electrocardiography

SD:: Sudden death

1SD:: One standard deviation

Se:: Sensitivity

s-EEG:: Surface/sphenoidal electroencephalography

Sp:: Specificity

SPECT:: Single-photon-emission computed tomography

STA:: Spectral turbulence analysis

TD:: Time domain

VAT:: Ventricular activation time

VF:: Ventricular fibrillation

VLP:: Ventricular late potentials

VT:: Ventricular tachyarrhythmia

## Introduction

Resective temporal lobe surgery, the removal of the epileptogenic zone or an amount of cerebral tissue necessary and sufficient for seizure control, has been shown to be an effective treatment for appropriately selected patients with drug resistant, complex partial seizures.(1-5) The success of such surgery depends, in part, on the accurate localization of the epileptogenic foci and whether these foci can be safely resected. In recent years, noninvasive technologies that can augment the electrophysiologic and neuropsychologic information needed for the localization of the epileptogenic foci have included computed tomography (CT), magnetic resonance imaging (MRI), positron emission tomography (PET), and single-photon-emission computed tomography (SPECT). Epileptogenic foci are most often identified by electroencephalograms (EEG). Some patients with foci that are poorly localized by noninvasive EEGs require intracranial electrode recordings for the localization of their foci. The surgical implantation of intracranial electrodes exposes patients to risks for serious complications; therefore, the use of PET or SPECT scans as an alternate noninvasive means to localize the foci has been under investigation.

PET and SPECT scans are technologies that record functional changes in brain areas that appear to be associated with the epileptogenic zone. Images from PET scans show the hypometabolism of glucose, while images from SPECT scans show blood hypoperfusion in the epileptogenic areas during the interictal period. Both metabolism of glucose and perfusion increase at the same sites when seizures commence. Interictal PET and SPECT scans and ictal SPECT scans appear to be clinically useful in the presurgical evaluation of patients with intractable, complex partial seizures.

This report summarizes our evaluation of the published information on the correlations of abnormalities seen on PET and SPECT scan images with the EEG-identified epileptogenic foci in patients who experience complex partial seizures. In addition, we reviewed the correlation of the sites indicated by PET and SPECT scans with the sites removed by surgery in patients having good outcomes. This assessment was undertaken at the request of the Health Care Financing Administration for an evaluation of the safety, effectiveness, and clinical utility of PET, using ^18^F-labeled 2-deoxy-2-fluoro-D-glucose (FDG) in the diagnosis and management of patients with focal or partial epilepsy.

## Methods

A computer literature search of the MEDLINE and Healthline databases from 1977 through 1996 was used to obtain references for review. Key words were "epileptic surgery" and "localization of epileptogenic foci." Additional references were obtained from citations in the retrieved articles. From the approximately 400 articles retrieved, data were extracted and analyzed from articles that reported on patients who received two or more diagnostic tests. All reports were on series of patients. Selection criteria for inclusion in the reports (e.g., exclusion of subjects with structural lesions) often were not clear and were not consistent between centers.

## Background

The estimated incidence rate for epilepsy is 30/100,000.(6) Of the estimated 1 million Americans who have epilepsy, the majority have partial epilepsy that appears to respond to medical therapy. An estimated 100,000 patients with partial epilepsy who fail medical management are thought to be potential candidates for epilepsy surgery. Currently, about 1,500 epilepsy surgeries are performed per year in the United States at an estimated cost per case of $25,000-$100,000.(7-9)

The goals of presurgical evaluation of potential candidates for epilepsy surgery are (1) identifying and delineating the epileptogenic foci and (2) determining whether the foci overlap brain areas that also serve essential functions.(10-12) The decision to proceed with epilepsy surgery can be made in many cases without the use of invasive EEG, PET, or SPECT and can result in good postsurgical outcomes. However, when a detailed history, careful observation of the seizures, and review of electrophysiologic, neuropsychologic, and structural imaging tests do not provide converging evidence, other diagnostic tests may be needed to localize the epileptogenic site. For such patients, along with others whose CT and MRI scans show a lesion at the suspected epileptogenic foci, good surgical outcomes can be expected.(6, 13, 14) Because of the successful results of epilepsy surgery, efforts have been made to identify more candidates for surgery by incorporating other tests in the presurgical evaluation and localization of the epileptogenic foci. These tests, such as intracranial EEG, PET, and SPECT, may help to localize the epileptogenic foci in patients who do not have demonstrable structural lesions and are without localized EEG recordings.

## Review of Published Data

Table 1 shows the percentage of patients whose epileptogenic foci were localized by invasive means compared with those whose foci were identified by surface EEG. Thadani et al(6) estimated that about 20 percent of his surgically treated epileptic patients could be selected on the basis of convergent findings obtained by MRI scanning, interictal and ictal EEG recordings, clinical seizure characteristics, and neuropsychologic testing. These individuals could be expected to do well postoperatively. A large majority of epileptic patients, therefore, may need multiple tests to localize the potentially resectable foci.

Table 1. Use of invasive electroencephalography to localize epileptogenic foci

| | | Localization by s-EEG | | Localization by i-EEG^b^
Reference | No. of Patients | Patient Selection^a^ | No. | Percentage | No. | Percentage
Gaillard(15) | 16 | Selected | 12 | 75 | 4 | 25
Gaillard(16) | 18 | Consecutive | 14 | 78 | 4 | 22
Jack(17) | 53 | Consecutive | 49 | 93 | 4 | 8
Markand(18) | 99 | Consecutive | 86 | 87 | 13 | 13
Leiderman(19) | 45 | Selected | 32 | 71 | 13 | 29
Theodore(20) | 32 | Referred | 17 | 53 | 15 | 47
Valk(21) | 11 | Selected | 9 | 82 | 2 | 18
Chee(22) | 40 | Retrospective | 29 | 73 | 11 | 28
Theodore(23) | 53 | Referred | 31 | 59 | 22 | 42
Swartz(24) | 37 | Selected | 21 | 57 | 16 | 43
SadZot(25) | 57 | Selected | 20 | 35 | 37 | 65
Leiderman(26) | 28 | Referred | 18 | 64 | 10 | 36
Rowe(27) | 51 | Selected | 18 | 35 | 33 | 65
Grunwald(28) | 40 | Consecutive | 25 | 63 | 15 | 38
Engel(29) | 264 | Unspecified | 91 | 35 | 173 | 66
Rowe(30) | 32 | Consecutive | 7 | 22 | 25 | 78
Ryding(31) | 14 | Unspecified | 10 | 72 | 4 | 29
Engel(32) | 25 | Consecutive | 17 | 68 | 8 | 32
Engel(33) | 50 | Consecutive | 23 | 46 | 27 | 54
Summary | 965 | | 529 | 55 (22-93) | 436 | 45 (8-78)

Note: Data describe localization of epileptogenic foci in patients with intractable complex partial seizures by surface/ sphenoidal electroencephalography (s-EEG) or by invasive electroencephalography (i-EEG).

a Selected=selected from an unspecified number of patients; consecutive=patients seen as enrolled in study; referred=patients referred to study clinic.

b Patients whose epileptic foci were presumably not satisfactorily localized by s-EEG. Some were confirmed as having seizures originating bilaterally, whereas others were not localized by i-EEG or s-EEG.

The data in Table 1 suggest, however, that less than half of the epileptic patients required intracranial EEG recordings for possible localization of the foci. The proportion of patients requiring invasive EEG varied from a low of 8 percent to a high of 78 percent in the various reports. The actual proportion at any given epilepsy center is not clear.(16-18, 28, 30, 32, 33)

Table 2 shows the reliability of PET images using FDG to demonstrate hypometabolism in brain areas that correlate with the epileptogenic foci identified by EEG. Although hypometabolism usually correlated with the EEG-indicated foci, some of the images appeared to show hypometabolic areas that were contralateral to the EEG-identified foci. Of the 370 patients with EEG-identified foci, FDG-PET images showed an ipsilateral hypometabolic area in 282 (76 percent) of the patients. The percentage of foci identified by FDG-PET varied from 62-100 percent in the reports. Seven of the 12 studies reported that in one or more patients, the PET image showed a hypometabolic area that was contralateral to the EEG-identified foci.

Table 2. Correlation of interictal positron-emission tomography with electroencephalography in epileptic patients

| | Patients With Foci Lateralized by EEG | | Ipsilateral Foci With PET^b^ | | Contralateral Foci With PET^b^
Reference | No. of Patients^a^ | No. | Percentage | No. | Percentage | No. | Percentage
Ho(34) | 35 | 35 | 100 | 29 | 83 | 4 | 11
Gaillard(16) | 18 | 18 | 100 | 16 | 89 | 0 | 0
Gaillard(15) | 16 | 13 | 81 | 9 | 69 | 0 | 0
Radke(35) | 30 | 30 | 100 | 25 | 83 | 0 | 0
Sadzot(25) | 57 | 37 | 65 | 29 | 78 | 1 | 3
Ryvlin(36) | 20 | 20 | 100 | 17 | 85 | 1 | 5
Debets(37) | 22 | 22 | 100 | 17 | 77 | 4 | 18
Engel(29) | 153 | 116 | 76 | 78 | 67 | 8 | 7
Stefan(38) | 10 | 8 | 80 | 8 | 100 | 0 | 0
Franck(39) | 21 | 18 | 86 | 13 | 62 | 2 | 11
Theodore(40) | 36 | 17 | 47 | 13 ^c^ | 93 | 0 | 0
Engel(33) | 50 | 36 | 72 | 28 | 78 | 3 | 8
Summary | 468 | 370 | 79 | 282 | 76 | 19 | 6

Note: The correlation of hypometabolic areas with unilateral epileptogenic foci were identified by either s-EEG or I-EEG.

a Patients selected from among an unspecified number of patients.

b Positron-emission tomography image shows hypometabolism ipsilateral to or contralateral to the epileptogenic foci lateralized by electroencephalography.

c Positron-emission tomography data available in only 14 of 17 EEG-foci-identified patients.

In a relatively large series of patients, Engel et al(29) reported that of the 116 patients, FDG-PET scans showed hypometabolism ipsilateral to the EEG-identified foci in 78 (67 percent) of the patients and hypometabolism contralateral to the foci in 8 (7 percent) of the patients. Leiderman et al(19) suggested that interictal, regional hypometabolism seen in FDG-PET scans correlated with the EEG-defined epileptogenic site in 70-80 percent of the patients with partial epilepsy and that the occasional noncorrelation of the PET scans may be caused by the dynamics of the metabolic changes over time.

Interictal SPECT scans of the distribution of ^99m^Tc-D, L-hexamethylene-propyleneamine oxime (HMPAO) have demonstrated hypoperfusion at the epileptogenic foci. Table 3 shows the correlation of these SPECT abnormalities with foci localized by surface EEG and/or intracranial electrode recordings. The reported results were highly variable, with SPECT images showing areas of hypoperfusion ipsilateral to the EEG-identified foci in only 322 (53 percent) of the 607 patients with EEG-lateralized epileptogenic foci; the percentage varied from 6-94 percent in the various reports. Interictal SPECT images showed hypoperfusion in an area contralateral to the EEG-identified foci in about 10 percent of the scans, ranging from 0-33 percent, as seen in the individual reports.

Table 3. Correlation of interictal single-photon-emission computed tomography with electroencephalography in epileptic patients

| | Patients With Foci Lateralized by EEG | | Ipsilateral Foci With ii-SPECT^b^ | | Contralateral Foci With ii-SPECT^b^
Reference | No. of Patients^a^ | No. | Percentage | No. | Percentage | No. | Percentage
Newton(41) | 73 | 73 | 100 | 36 | 50 | 9 | 12
Carrilho(42) | 26 | 26 | 100 | 15 | 58 | 2 | 8
Franceschi(43) | 28 | 28 | 100 | 6 | 21 | 2 | 10
Spina(44) | 40 | 28 | 70 | 12 | 43 | | 00
Harvey(45) | 15 | 15 | 100 | 14 | 93 | 1 | 7
Launes(46) | 47 | 47 | 100 | 31 | 66 | 6 | 13
Yaxin(47) | 40 | 23 | 58 | 9 | 39 | 3 | 13
Duncan(48) | 63 | 27 | 43 | 11 | 41 | 9 | 33
Verhoeff(49) | 28 | 25 | 89 | 9 | 36 | 3 | 12
Ryvlin(36) | 20 | 20 | 100 | 11 | 55 | 0 | 0
Jabbari(50) | 58 | 43 | 74 | 20 | 47 | 0 | 0
Rowe(27) | 51 | 46 | 90 | 18 | 39 | 3 | 7
Duncan(51) | 30 | 9 | 30 | 5 | 6 | 0 | 0
Cordes(52) | 52 | 37 | 71 | 30 | 81 | 9 | 24
Duncan(53) | 30 | 17 | 57 | 10 | 59 | 0 | 0
Kawamura(54) | 44 | 30 | 68 | 9 | 30 | 4 | 13
LaManna(55) | 19 | 18 | 95 | 17 | 94 | 1 | 6
Rowe(30) | 32 | 30 | 94 | 17 | 57 | 3 | 10
Mitsuyoshi(56) | 24 | 17 | 71 | 11 | 65 | 3 | 18
Ryding(31) | 14 | 13 | 93 | 9 | 69 | 1 | 8
Lee(57) | 16 | 14 | 88 | 9 | 64 | 1 | 7
Stefan(38) | 10 | 8 | 80 | 6 | 75 | 1 | 13
Stefan(58) | 16 | 13 | 81 | 9 | 69 | 0 | 0
Summary | 776 | 607 | 78 | 322 | 53 | 61 | 10

Note: The correlation of hypoperfusion sites was demonstrated by interictal single-photon-emission computed tomography (ii-SPECT) with the unilateral epileptogenic foci identified by either s-EEG or i-EEG.

a Patient selection criteria were not explicit. Some patients may have been included in more than one of the cited reports.

b Hypoperfusion site by SPECT found ipsilateral to or contralateral to the epileptogenic foci lateralized by EEG.

Abbreviations: s-EEG=surface/sphenoidal electroencephalography; i-EEG=invasive electroencephalography.

Ictal and postictal SPECT images have been obtained with HMPAO or ^123^I-N, N, N'-trimethyl-N'-(2-hydroxy-3-methyl-5-iodobenzyl)-1, 3-propanediamine (HIPDM). These studies showed areas of hyperperfusion that were better correlated with the EEG-localized epileptogenic foci than the hypoperfusion seen on interictal SPECT images. As seen in Table 4, ictal SPECT scans showed hyperperfusion at the EEG-identified foci in 128 (95 percent) of the 135 patients; postictal scans obtained in 106 patients showed hyperperfusion ipsilateral to the EEG-lateralized foci in 76 (72 percent) of patients. Ictal scans did not show any discordant hyperperfusion in any of the images, but two of the postictal scans did show hyperperfusion discordant or contralateral to the EEG-identified foci.

Table 4. Correlation of ictal and postictal single-photon-emission tomography with electroencephalography in epileptic patients

| | Patients With Foci Lateralized by EEG | | Ipsilateral Foci With I-/p-SPECT^b^ | | Contralateral Foci With I-/p-SPECT^b^
Reference | No. of Patients^a^ | No. | Percentage | No.^c^ | Percentage | No. | Percentage
Ho(34) | 35 | 35 | 100 | 33/35 ^i^ | 94 | 2 | 6
Newton(41) | 73 | 73 | 100 | 49/50 ^i^ 22/31 ^p^ | 97 72 | 0 2 | 0 5
Harvey(45) | 15 | 15 | 100 | 14/15 ^i^ | 93 | 0 | 0
Marks(59) | 11 | 8 | 73 | 5/7 ^i^ | 71 | 0 | 0
Newton(60) | 12 | 12 | 100 | 12/12 ^i^ | 100 | 0 | 0
Rowe(61) | 51 | 45 | 88 | 31/45 ^p^ | 69 | 0 | 0
Rowe(30) | 32 | 32 | 94 | 23/30 ^p^ | 77 | 0 | 0
Lee(57) | 16 | 14 | 88 | 13/14 ^i^ | 93 | 0 | 0
Ryding(31) | 14 | 14 | 100 | 2/2 ^i^ | 100 | 0 | 0
| | Ictal SPECT | | 128/135 ^i^ | 95
| | Postictal SPECT | | 76/106 ^p^ | 72

Note: The correlation of hypoperfusion sites was shown by ictal or postictal single-photon-emission computed tomography (I-SPECT or p-SPECT) with unilateral epileptogenic foci identified by either s-EEG or i-EEG.

a Patients selected from among unspecified number of patients.

b SPECT scans showed hypoperfusion sites that were either ipsilateral or contralateral to the epileptogenic foci lateralized by EEG.

c numbers represent those showing hypoperfusion over the number of patients that were successfully injected with the tracer compound during the periictal period.

Abbreviations: s-EEG=surface/sphenoidal electroencephalography; i-EEG =invasive electroencephalography;

i=ictal SPECT results;

p=postictal SPECT results.

Good outcomes, defined as becoming seizure free or having a reduction in seizure frequency of more than 75 percent, have been reported for a majority of patients who have had epilepsy surgery. These outcomes may reflect, in part, the careful evaluation and selection of patients before brain surgery. The number of patients identified who benefited from the use of invasive EEG and noninvasive PET and SPECT scans is not clear. Tables 5 and 6 summarize studies on the correlations of presurgical FDG-PET and SPECT scans to patients who had good surgical outcomes.

Table 5 shows that, of the 216 patients who had good surgical outcomes, 178 (82 percent) showed FDG-PET abnormalities that were congruent with the sites removed by surgery; the decision to proceed with the epilepsy surgery was made without consideration of the PET image in most of the studies. The percentage of patients with good outcomes that were identified by FDG-PET scans varied from a low of 58 percent by Theodore et al(20) to a high of 100 percent by Gaillard et al(15) and Olson et al.(63) The latter two reports were results obtained in epileptic children. Among the 38 patients with good outcomes, FDG-PET scans were normal in 10.(20) The scans showed hypometabolism contralateral to the ictal site in one patient(24) and hypermetabolism at the epileptic foci in one patient.(63) Of the 36 patients who had no improvement, 8 showed FDG-PET abnormalities at the resected sites.(23, 35)

Table 5. Correlation of fluorodeoxyglucose-positron-emission tomography scans with surgical outcomes

Reference | No. of Patients Who Received Operations^a^ | No. With Good Outcome^b^ | | PET Scan Concordant With Good Outcome | | Comments
  No. | Percentage
  No. | Percentage
Gaillard(16) | 9 adults | 8 FU=11-38 | 89 | 7/8 | 88 | Pathologic lesions were found in 6/9 patients.
Gaillard(15) | 10 children | 9 FU=3-82 | 90 | 9/9 | 100 | Ten of 13 patients with unilateral EEG focus underwent operations. Nine of 13 patients showed hypometabolism psilateral to EEG focus. Selection criteria for surgery were not stated.
Theodore(20) | 32 | 26 FU=32 S.D.=18 | 81 | 15/26 | 58 | Surgical decision was based only on EEG data. Fifteen of 16 (93%) patients with positive PET had good outcome, and 10/16 (63%) with negative PET had good outcome. MRI abnormality was evident in 18 of 26 patients with good outcome.
Heinz(62) | 27 | 24 FU=>12 mean=21 | 89 | 17/24 | 71 | MRI identified 20/24 (83%) of improved patients. MRI identified 17/19 (89.5%) of histologic abnormalities. PET identified 15/19 (79%) of histologic abnormalities.
Valk(21) | 11 | 11 FU=24-48 | 100 | 10/11 | 91 | All patients were selected on basis of probable mesial temporal gliosis and had no structural lesions by MRI. Epileptogenic focus localized by ictal and interictal EEGs. Two patients required subdural electrode EEG. One of 2 patients requiring subdural EEG had normal PET scan.
Chee(22) | 38 | 32 FU=12 | 84 | 25/32 | 78 | Retrospective study. PET was concordant with 29/31 (93.5%) EEG foci. Excluded patients with extratemporal foci.
Radke(35) | 30 | 26 FU=24-40 | 87 | 24/26 | 92 | Retrospective study. Selection criteria for surgery were not stated. One of 25 positive PET was not significantly improved.
Theodore(23) | 53 | 39 FU=14-29 | 74 | 35/39 | 90 | Surgical decision was based only on EEG data. Twenty-two of 53 (42%) patients had subdural EEG. PET may have obviated subdural EEG in 8/22 (38%) patients. Seven of 46 positive PET were not significantly improved.
Swartz(24) | 34 | 340 FU=20-71 | 10 | 28/34 | 82 | PET showed false lateralization in one patient. Sixteen of 37 (45%) patients required intracranial EEG.
Olson(63) | 8 children | 7 FU=4-27 | 88 | 7/7 | 100 | Two seizure-free patients had focal hypometabolism congruent with removed site and also showed additional EEG sites. Hypermetabolism was seen at epileptic focus in patient with electrical discharges.
Summary | 252 | 216/252 | 86 (74-100) | 178/216 | 82 (58-100)

Note: Data are from studies of patients with intractable complex partial seizures who had FDG-PET scans in addition to the usual presurgical evaluations. Surgical decisions apparently were made without consideration of the PET scans in most studies.

a Patients selected for these studies were not specified, nor were the criteria used to proceed with the surgery.

b Good outcomes included seizure-free patients and, in most cases, those who had seizure frequency reductions greater than 75 percent.

Abbreviation: FU=followup, given in months.

Table 6 shows the varying correlations of the presurgical SPECT images with the EEG-localized epileptogenic foci in patients with good surgical outcomes. Surgical decisions were based on electrophysiologic, neuropsychologic, and other information without consideration of the SPECT images. Good outcomes were observed in 187 (79 percent) of the 236 patients. Of those patients with good outcomes, 152 had either an ictal or postictal SPECT scan with 119 (78 percent), showing hyperperfusion at the site removed by surgery. The better correlation of ictal SPECT scans in these patients was reported by Markand et al,(64) where 46 (82 percent) of 56 ictal SPECT images showed hyperperfusion at the site corresponding to the epileptogenic foci; only 12 (55 percent) of 22 postictal images showed hypermetabolism corresponding to the foci. In comparison, interictal SPECT scans done in 104 patients with good outcomes showed hypoperfusion at the site removed by surgery in 61 (59 percent) of the patients. Grunwald et al(28) reported that interictal hypoperfusion contralateral to the resected epileptogenic site was seen in only 9 (32 percent) of the 28 seizure-free patients.

Table 6. Correlation of single-photo-emission computed tomography with surgical outcomes

Reference | No. of Patients Who Received Operations^a^ | No. With Good Outcome^b^ | | SPECT Scan Concordant With Good Outcome | | Comments
  No. | Percentage
  No. | Percentage
Jack(17) | 53 | 43 FU=12-40 | 81 | 19/43 Interictal (HMPAO) | 45 | Surgery based on ictal and interictal electroclinical criteria. Four of 53 had depth electrode EEG. Patients with structural lesions excluded.
Markand(64) | 90 | 68 FU=6-97 | 76 | 46/56 Ictal (HIPDM) 12/22 Postictal (HMPAO) | 82 55 | Eighty-six of 99 (87%) foci localized by interictal and ictal EEG (noninvasive). Thirteen localized by intracranial EEG. Facile ictal injection of HIPDM, but not HMPAO (require reconstitution time).
Adams(65) | 15 | 15 FU=2-27 | 100 | 4/4 Postictal (HMPAO) | 100 | Five of 20 had less than 1-month FU and were not included in analysis. Nineteen of 20 correctly localized by EEG without invasive subdural EEG. Eight of 20 (40%) pathologic foci identified by interictal SPECT. No intracranial electrode studies.
Markand(18) | 38 | 33 FU=5-42 | 87 | 31/33 Ictal (HIPDM) 23/33 Interictal (HIPDM) | 94 70 | Surgery decision based on ictal and interictal EEG; confirmatory localization by SPECT helpful in 16/38 (42%) of patients; no intracranial EEG. Ictal SPECT may have identified 31/33 or 94% of patients with good outcome. Thirty-one of 34 (91%) of ictal SPECT scans show temporal localization.
Rowe(61) | 41 | 37 | 90 | 26/37 Postictal (HMPAO) | 70 | Seizure foci were determined to be clearly unilateral in 45/51 by ictal EEG with intracerebral or sphenoidal electrodes.
Grunwald(28) | 40 | 28 FU=>12 | 70 | 19/28 Interictal (HMPAO) (seizure-free patients) | 68 | Surgery was directed by surface EEG, video-EEG monitoring, and electrocorticogram in 15 patients. Nine of 28 (32%) seizure-free patients showed contralateral interictal hypoperfusion. Ten of 40 (25%) were reported to have improved seizure frequency with 2/40 showing no improvement.
Summary: ictal and postictal SPECT | | | | 119/152 | 78 (55-100)
Summary: interictal SPECT | 236 | 187/236 | 79 (70-100) | 61/104 | 59 (45-70)

Note: Patients with intractable complex partial seizures who had SPECT scans in addition to the usual presurgical evaluations. The scans were obtained in the interictal, postictal, and/or ictal period. The basis for the selection of patients for surgery was not stated in some of the studies.

a Patient selection for these studies was not specified.

b Good outcome included seizure-free patients and, in most cases, those who had seizure frequency reductions greater than 75 percent.

99m Abbreviations: FU=followup, given in months; HIPPDM=I-N, N, N'-trimethyl-N'-(2 hydroxy-3-methyl-5-1231-iodobenzyl)-1, 3-propanediamine; HMPAO=Tc-D, L-hexamethylene-propyleneamine oxime.

## Discussion

Patients with intractable complex partial seizures often have surface EEG findings that indicate a focus that does not agree with the clinical symptoms or a focus that is bilateral, contralateral, or diffuse and nonlocalizing. In attempts to localize the epileptogenic foci in these patients, intracranial electrode recordings, FDG-PET scans, SPECT scans, and magnetoencephalography(66) have been used in some epilepsy centers.

In the management of epilepsy patients, the possible role of FDG-PET scans depends on the reliability with which PET images can show hypometabolic areas that correspond to the EEG-identified foci. Ultimately, in patients with good outcomes, the area with the localized PET abnormality should correspond to the resected area. From the reports in Table 2, PET images have shown hypometabolic areas that were concordant with the EEG-identified foci in about 76 percent of the cases. This suggests that if PET were to be used as a confirmatory test, about a quarter of the "epileptogenic foci" might not be seen. Of greater concern, some of the PET scans showed hypometabolic areas that were discordant with the EEG-identified foci. Without knowing which of the two "foci" is actually epileptogenic when the EEG recording and the FDG-PET scan are not in agreement, the resection of foci localized by EEG may have resulted in good outcomes in 80-90 percent of the patients with agreement of FDG-PET scans in 82 percent of these cases (Tables 5 and 6). Some of the patients who showed no improvement may have had a seizure focus localized by PET scans in the contralateral, unresected area. However, Theodore et al(20) reported that positive PET scans have an excellent positive predictive value of 93 percent (15/16 positive scans), while 10 of the 16 remaining patients with negative PET scans also had good outcomes (Table 5). In sum, PET scans did not detect the epileptogenic sites or indicate discordant foci in 63 percent of their patients.

Although invasive EEG may be helpful in localizing the epileptogenic site, patients are exposed to the risks associated with the intracranial implantation of the electrodes. Whether PET scans might serve as an alternative to invasive EEG and, therefore, avoid these risks would depend on the correlation of the FDG-PET scans with the invasive EEG recordings. According to a retrospective review of 147 patients by Engel et al,(29) FDG-PET scans might have substituted for depth electrode recordings in about 90 percent of the patients. Mazziotta(67) estimated that PET scans might obviate the need for invasive EEGs in about 33-50 percent of patients, and Theodore et al(23) reported that PET scans may have substituted for 8 (38 percent) of the 22 subdural electrode recordings. Thus, the extent to which and under what circumstances noninvasive PET scans might effectively substitute for invasive EEGs remains uncertain.

The false localization of the epileptogenic foci by FDG-PET scans in some patients is of great concern if FDG-PET scans are substituted for invasive EEG. Except for Engel et al,(29) who implied that the seizure origin site may have been indicated by the PET scan and not by the invasive EEG in two patients, others have found that the invasive EEG foci correlated with the seizure origin site. For example, Sperling et al(68) found that the removal of the EEG-identified area resulted in good outcomes in two patients who had FDG-PET abnormalities in the contralateral areas. Sadzot et al(25) noted that one patient, whose PET scan showed a focus in the contralateral temporal lobe, became seizure-free after temporal lobectomy on the side of the focus defined by intracranial EEG. Levesque et al(69) reported that FDG-PET may falsely lateralize 2 percent and falsely localize 6 percent of the patients. Similar false localization of the foci with FDG-PET scans in children who had good surgical outcomes with the resection of the EEG-identified foci have been reported.(70)

In comparison to PET scans, interictal SPECT scans do not appear to be particularly reliable; only about half of the patients with EEG-localized foci showed interictal SPECT abnormalities that were concordant with the EEG-identified foci (Table 3). In addition to the relative inability to identify the foci, interictal SPECT scans tended to show hypoperfusion in areas contralateral to the EEG-identified foci in a substantial number of patients. Although some reports, such as those by LaManna et al,(55) Harvey et al,(45) and Cross et al,(71) appear to contradict this by finding that almost all of the foci were identified by interictal SPECT, most epilepsy centers suggest that interictal SPECT is not a very reliable method for the demonstration of the foci.

Ictal and postictal SPECT scans, on the other hand, have shown a greater reliability for demonstrating hyperperfusion at the EEG-identified foci. Ictal SPECT scans appear to be more reliable for identifying almost all (95 percent) of the foci, whereas the postictal SPECT scans are less reliable (Table 4). Ictal SPECT scans seem to be the preferred method for demonstrating the epileptogenic foci. However, the timing of injection of the radiolabeled compound for ictal or postictal scans seems to be very critical, because the hyperperfusion spreads away from the foci very rapidly after the onset of the seizure and subsides quickly afterwards.(59, 60, 71) Although postictal scans have shown hyperperfusion at the foci in a significant number of patients, the reliability of detecting hyperperfusion postictally depends heavily on the timing of the injection of the tracer and on the rate of change in the perfusion at the foci and in other areas of the brain. Rowe et al(60) noted that a delay in injecting the tracer after cessation of the seizure markedly changed the hyperperfusion as seen on the postictal scans. If the tracer was injected within a minute of seizure cessation, scans of the area showed hyperperfusion in most patients similar to ictal scans. This rapid change in perfusion was illustrated in a child with temporal lobe epilepsy, as reported by Cross et al.(71) The ictal scan obtained by injecting the tracer 55 seconds after onset of the seizure showed focal hyperperfusion of the left temporal lobe. The postictal scan obtained by injecting the tracer 43 seconds after seizure cessation showed medial hyperperfusion of the left temporal lobe with lateral hypoperfusion. Thirty minutes after seizure cessation, the interictal scan, obtained by the injection of the tracer, showed hypoperfusion of the whole left temporal lobe. This rapid spread of hyperperfusion to other parts of the brain and the hypometabolism in areas surrounding the epileptogenic foci have led to difficulties in interpretation of the images and accurate identification of the foci.

Whether PET or SPECT scans might be useful in predicting surgical outcome has yet to be determined. Tables 5 and 6 showed that FDG-PET scans identified about 82 percent and SPECT scans a variable percentage of patients who had good surgical outcomes. Normal PET scans in some of the patients who had good outcomes, and positive scans for the resected tissue in some who showed no change in seizure status, are of significance and require further study with regard to FDG-PET scans. SPECT scans, on the other hand, showed abnormal perfusion in varying numbers of patients, depending on whether the scan was done during the interictal, ictal, or postictal state. Interictal SPECT scans identified only 45-70 percent of patients, and postictal and ictal SPECT scans identified 55-100 percent of patients with good surgical outcomes. In comparison to PET scans and other modes of SPECT scans, ictal SPECT scans appear to be the most reliable for identifying seizure foci. Ho et al(34) retrospectively reviewed selected patients with well-lateralized temporal lobe epilepsy and showed that ictal SPECT scans correctly identified more of the foci (94 percent) than FDG-PET (83 percent) with no disagreement between the two independent interpreters of the images. However, the procedures for obtaining a reliable ictal SPECT image, especially the timing of the injection of the tracer compound, need further investigation.

### Outside Comments

The following comments were among those received in response to our Federal Register request for information. The National Association of Epilepsy Centers stated that noninvasive EEG recordings provide the most important information for localizing an epileptogenic region in patients with medically refractory epilepsy. The noninvasive recordings may falsely localize or falsely lateralize the foci in 10-20 percent of the patients and necessitate the use of other tests to determine the location of the foci and the suitability of these patients for surgery. Although these statements are in agreement with our findings, we do not agree with the recommendation that FDG-PET scans be performed as a confirmatory test in all patients, because the majority of patients may be found suitable for surgery based on noninvasive EEG recordings and other information such as clinical symptoms and neurologic/neuropsychologic test results. Consequently, although a confirmatory PET scan may be useful, these expensive scans may be needed in only a minority of the patients.

Comments received from the Institute for Clinical PET do not clarify when PET scans might be appropriate except that the scans may help increase the certainty of the localization of the ictal onset zone and optimize the selection of the intracranial electrode placement sites. In agreement with our findings, the Institute acknowledges that FDG-PET scans detect temporal lobe hypometabolism in only 70-90 percent of the patients with temporal lobe epilepsy and that the hypometabolism is falsely lateralized in some cases.

### U.S. Public Health Service Comments

The National Institutes of Health stated that the sensitivity of FDG-PET scans is approximately equal to that of properly performed MRI and ictal SPECT for identifying an area that corresponds to the epileptogenic foci. A relatively limited use for PET scans in patients who have normal MRI scans and in children with secondary generalized epilepsies such as Lennox-Gastaut syndrome or infantile spasms is suggested.

## Summary

Currently available methods for the localization of epileptogenic foci in patients with intractable complex partial seizures have led to the identification and selection of patients who have subsequently undergone curative epilepsy surgery. A majority of these patients (about 75 percent) have become seizure-free or have had their seizure frequency reduced by greater than 75 percent. Noninvasive surface EEG recordings and information obtained from clinical observations, CT and/or MRI, and neuropsychologic tests have enabled the identification of most of these patients. Other tests, such as invasive EEG, PET scans, and SPECT scans, have been used at various epilepsy centers to identify additional candidates who might benefit from surgery and to improve the probability of obtaining good surgical outcomes.

In many epileptic patients, PET and SPECT scans may be useful for the presurgical identification of epileptogenic foci or confirmation of the foci indicated by EEG. FDG-PET scans have shown hypometabolic areas that correspond to the foci localized by EEG in about 70-80 percent of the patients. Interictal SPECT scans have shown hypoperfusion at the EEG-identified foci in about 50 percent of the patients. However, both methods appear to miss a substantial number of EEG-identified foci and both appear to indicate abnormalities that are discordant with the EEG localization. This discordance seems to be more prevalent with interictal SPECT. Ictal SPECT scans seem to avoid this problem and demonstrate abnormal hyperperfusion in areas that coincide with the EEG-identified foci. Postictal SPECT scans are less reliable, especially if tracer is not injected within a very short time after cessation of the seizure.

It is not clear whether PET or SPECT scans can independently localize epileptogenic foci and identify additional patients as candidates for epilepsy surgery, or whether they simply serve as supplemental means of localizing the foci. Although PET or SPECT may show functional abnormalities that correspond to the EEG-foci, the definitive proof that PET or SPECT scans can identify the epileptogenic foci and predict the eventual surgical outcome is lacking.

Interictal SPECT scans are not particularly useful in identifying either EEG-identified foci or the patients with good surgical outcomes. Postictal SPECT scans may more reliably identify the foci, but ictal SPECT scans would be the most reliable means of identifying the epileptogenic foci and the patients likely to benefit from epilepsy surgery. Although the sparseness of the data for ictal SPECT scans prevents any conclusions about its reliability and utility in diagnosis and management of epileptic patients, the results to date indicate that there are possibilities that ictal SPECT might serve as an alternative method to invasive EEG in patients who have epileptogenic foci that are difficult to localize.

Intracranial electrode recordings have been used to clarify the ambiguous findings of surface EEGs. They may identify some patients as candidates for epilepsy surgery among those who would not have been considered for surgery. The presently available information does not show that PET or SPECT scans have led to the similar identification of additional patients. More data are necessary to determine when and under what conditions the FDG-PET scans can be relied upon as a substitute for the management of epileptic patients. In view of the difficulties of interpreting some of the PET images, a concordant finding with PET may confirm the epileptic foci, but if the scan is discordant, the true foci may be in question. Further studies are needed to address (1) the presurgical identification of the epileptogenic foci in the 82 percent of the patients who had good surgical outcomes, (2) the finding of hypometabolic foci in the resected tissue in patients who had no postsurgical improvement in their epileptic status, and (3) the apparent false localization of the foci in some patients (especially those who had good surgical outcomes). The results of such studies are needed before a role for FDG-PET scans in complex partial seizure can be defined.

## Glossary

Computed tomography (CT):: Photographic outline of structures resulting from computer analysis of data.

Contralateral:: Opposite side.

Electroencephalogram (EEG):: Graphic recording of electrical brain activity.

Epileptogenic foci:: Brain site of origin of seizure.

Fluorodeoxyglucose-positron-emission tomography (FDG-PET):: Computed tomographic image of internal distribution of derivative of glucose labeled with radioactive fluoride.

Hypometabolism:: Decreased utilization of nutrient in tissue.

Hypoperfusion:: Decreased circulation of blood to tissue.

Ictal:: Active seizure phase.

Ictal SPECT (I-SPECT):: Computed tomographic image of internal distribution of radiolabeled chemical during a seizure.

Interictal:: Interphase between seizures.

Invasive or intracranial electroencephalography (I-EEG):: Electroencephalogram recorded with electrodes in the cranium.

Ipsilateral:: Same side.

Magnetic resonance imaging (MRI):: Computed tomographic image of varying magnetic resonances in cells of the body.

Noninvasive EEG:: Electroencephalogram recorded with electrodes on surface of the head.

Positron emission tomography (PET):: Computed tomographic image of internal distribution of radiolabeled chemical.

Postictal SPECT (p-SPECT):: Computed tomographic image of internal distribution of radiolabeled chemical immediately after seizure stops.

Reliability:: Dependability.

Resective temporal lobe surgery:: Removal of temporal lobe by surgery.

Single-photon-emission computed tomography (SPECT):: Computed tomographic image of internal distribution of radiolabeled chemical.

Surface/sphenoidal:: Outside of the cranium.

## References

1 Cummings TJ, Chugani DC, Chugani HT. Positron emission tomography in pediatric epilepsy Surg Treatment Epilepsy Child 1995 6:465 472
2 Engel J Jr. Update on surgical treatment of the epilepsies. Summary of the Second International Palm Desert Conference on the Surgical Treatment of the Epilepsies (1992) Neurology 1993 43:1612 1617 8102482
3 King DW, Flanigin HF, Gallagher BB, et al. Temporal lobectomy for partial complex seizures: Evaluation, results, and 1-year follow-up Neurology 1986 36:334 339 3951699
4 Goldring S, Gregorie EM. Surgical management of epilepsy using epidural recording[s] to localize the seizure focus. Review of 100 cases J Neurosurg 1984 60:457 466 6699689
5 Rapport RL, Ojeman Ojemann GA, Wyler AR, et al. Surgical management of epilepsy West J Med 1977 127:185 189 410163
6 Thadani VM, Williamson PD, Berger R, et al. Successful epilepsy surgery without intracranial EEG recording: Criteria for patient selection Epilepsia 1995 36:7 15 8001512
7 Rainwater MR, Ricker BR, Tempkin NR, et al. Direct medical costs and cost savings with epilepsy surgery Epilepsia 1993 334(Suppl 2):
8 Vickrey BG, Hays RD, Graber J, et al. A health-related quality of life instrument for patients evaluated for epilepsy surgery Medical Care 1992 30:299 319 1556879
9 Awad IA, Nayel MH, Luders H. Second operation after the failure of previous resection for epilepsy Neurosurgery 1991 28:510 518 2034344
10 Engel J Jr. Surgery for seizures New Engl J Med 1996 334:647 652 8592530
11 Oliver B, Russi A. What is needed for resective epilepsy surgery from a neurosurgical point of view? Acta Neurol Scand 1994 Suppl 152:187 189
12 Polkey CE. What is needed from the neurosurgical point of view Acta Neurol Scand 1994 Suppl 152:183 186
13 Ojemann LM, Ojemann GA, Dodrill CB, et al. Outcome of seizure control in a surgical group compared to a nonoperated control group of patients with temporal lobe epilepsy Epilepsia 1992 33(Suppl 3):
14 Walczak TS, Radtke RA, McNamara, et al. Anterior temporal lobectomy for complex partial seizures: Evaluation, results, and long-term follow-up in 100 cases Neurology 1990 40:413 420 2314581
15 Gaillard WD, White S, Malow B, et al. FDG-PET in children and adolescents with partial seizures: Role in epilepsy surgery evaluation Epilepsy Res 1995 20:77 84 7713062
16 Gaillard WD, Bhatia S, Bookheimer SY, et al. FDG-PET and volumetric MRI in the evaluation of patients with partial epilepsy Neurology 1995 45:123 126 7824101
17 Jack CR Jr, Mullan BP, Sharbrough FW, et al. Intractable nonlesional epilepsy of temporal lobe origin: Lateralization by interictal SPECT versus MRI Neurology 1994 44:829 836 8190283
18 Markand ON, Salanova V, Worth RM, et al. Ictal brain imaging in presurgical evaluation of patients with medically intractable complex partial seizures Acta Neurol Scand 1994 Suppl 152:137 144
19 Leiderman DB, Albert P, Balish M, et al. The dynamics of metabolic change following seizures as measured by positron emission tomography with fludeoxyglucose F 18 Arch Neurol 1994 51:932 936 8080394
20 Theodore WH, Gaillard WD, Sato S, et al. Positron emission tomographic measurement of cerebral blood flow and temporal lobectomy Ann Neurol 1994 36:241 244 8053663
21 Valk PE, Laxer KD, Barbaro NM, et al. High-resolution (2.6-mm) PET in partial complex epilepsy associated with mesial temporal sclerosis Radiology 1993 186:55 58 8416586
22 Chee MW, Morris HH 3d, Antar MA, et al. Presurgical evaluation of temporal lobe epilepsy using interictal temporal spikes and positron emission tomography Arch Neurol 1993 50:45 48 8418799
23 Theodore WH, Sato S, Kufta C, et al. Temporal lobectomy for uncontrolled seizures: The role of positron emission tomography Ann Neurol 1992 32:789 794 1471870
24 Swartz BE, Tomiyasu U, Delgado-Escueta AV, et al. Neuroimaging in temporal lobe epilepsy: Test sensitivity and relationships to pathology and postoperative outcome Epilepsia 1992 33:624 634 1628575
25 Sadzot B, Debets RM, Maquet P, et al. Regional brain glucose metabolism in patients with complex partial seizures investigated by intracranial EEG Epilepsy Res 1992 12:121 129 1396538
26 Leiderman DB, Balish M, Sato S, et al. Comparison of PET measurements of cerebral blood flow and glucose metabolism for the localization of human epileptic foci Epilepsy Res 1992 13:153 157 1464300
27 Rowe CC, Berkovic SF, Austin MC, et al. Visual and quantitative analysis of interictal SPECT with technetium-^99m^-HMPAO in temporal lobe epilepsy J Nucl Med 1991 32:1688 1694 1880570
28 Grunwald F, Durwen HF, Bockisch A, et al. Technetium-^99m^-HMPAO brain SPECT in medically intractable temporal lobe epilepsy: A postoperative evaluation J Nucl Med 1991 32:388 394 2005445
29 Engel J Jr, Henry TR, Risinger MW, et al. Presurgical evaluation for partial epilepsy: Relative contributions of chronic depth-electrode recordings versus FDG-PET and scalp-sphenoidal ictal EEG Neurology 1990 40:1670 1677 2122275
30 Rowe CC, Berkovic SF, Sia ST, et al. Localization of epileptic foci with postictal single photon emission computed tomography Ann Neurol 1989 26:660 668 2817840
31 Ryding E, Rosen I, Elmqvist D, et al. SPECT measurements with ^99m^Tc-HM-PAO in focal epilepsy J Cereb Blood Flow Metab 1988 8:S95 100 3142889
32 Engel J Jr, Brown WJ, Kuhl DE, et al. Pathological findings underlying focal temporal lobe hypometabolism in partial epilepsy Ann Neurol 1982 12:518 528 6984318
33 Engel J Jr, Kuhl DE, Phelps ME, et al. Comparative localization of epileptic foci in partial epilepsy by PCT and EEG Ann Neurol 1982 12:529 537 6818897
34 Ho SS, Berkovic AF, Berlangieri SU, et al. Comparison of ictal SPECT and interictal PET in the presurgical evaluation of temporal lobe epilepsy Ann Neurol 1995 37:738 745 7778847
35 Radke Radtke RA, Hanson MW, Hoffman JM, et al. Temporal lobe hypometabolism on PET: Predictor of seizure control after temporal lobectomy Neurology 1993 43:1088 1092 8170547
36 Ryvlin P, Philippon B, Cinotti L, et al. Functional neuroimaging strategy in temporal lobe epilepsy: A comparative study of ^18^FDG-PET and 99mTc-HMPAO-SPECT Ann Neurol 1992 31:650 656 1514777
37 Debets RM, van Veelen CW, Maquet P, et al. Quantitative analysis of 18/FDG-PET in the presurgical evaluation of patients suffering from refractory partial epilepsy. Comparison with CT, MRI, and combined subdural and depth EEG Acta Neurochir Suppl (Wien) 1990) 50:88 94 2097891
38 Stefan H, Pawlik G, Bocher-Schwarz HG, et al. Functional and morphological abnormalities in temporal lobe epilepsy: A comparison of interictal and ictal EEG, CT, MRI, SPECT, and PET J Neurol 1987 234:377 384 3498801
39 Franck G, Sadzot B, Salmon E, et al. Regional cerebral blood flow and metabolic rates in human focal epilepsy and status epilepticus Adv Neurol 1986 44:935 948 3085438
40 Theodore WH, Dorwart R, Holmes M, et al. Neuroimaging in refractory partial seizures: Comparison of PET, CT, and MRI Neurology 1986 36:750 759 3084995
41 Newton MR, Berkovic SF, Austin MC, et al. Ictal postictal and interictal single-photon emission tomography in the lateralization of temporal lobe epilepsy Eur J Nucl Med 1994 21:1067 1071 7828616
42 Carrilho PG, Yacubian EM, Cukiert A, et al. MRI and brain SPECT findings in patients with unilateral temporal lobe epilepsy and normal CT scan Arq Neuropsiquiatr 1994 52:149 152 7826242
43 Franceschi M, Messa C, Ferini-Strambi L, et al. SPECT SPET imaging of cerebral perfusion in patients with non-refractory temporal lobe epilepsy Acta Neurol Scand 1993 87:268 274 8503254
44 Spina A, Damato R, Losito R, et al. Correlations between abnormalities on brain SPECT scan and interictal EEG-foci in children with "intractable" partial epilepsy Acta Neurol (Napoli) 1993 15:321 327 8304079
45 Harvey AS, Bowe JM, Hopkins IJ, et al. Ictal 99mTc-HMPAO single photon emission computed tomography in children with temporal lobe epilepsy Epilepsia 1993 34:869 877 8404739
46 Launes J, Iivanainen M, Salmi T, et al. Interictal brain 99Tc-HM-PAO SPECT hypoperfusion in patients with unstable partial epilepsy and normal CT Acta Neurol Scand 1992 86:558 562 1481640
47 Yaxin F, Xiuqin L, Meifang Y, et al. Comparative study of 99mTc-HM-PAO SPECT brain imaging, EEG, and CT scanning in epileptic patients during the interictal period Clin Med Sci J 1992 7:5 8
48 Duncan S, Gillen G, Adams FG, et al. Interictal HM-PAO SPECT: A routine investigation in patients with medically intractable complex partial seizures? Epilepsy Res 1992 13:83 87 1478200
49 Verhoeff NP, Weinstein HC, Aldenkamp AP, et al. Focus localization in patients with partial epilepsy with 99Tcm-HMPAO SPECT under continuous surface EEG monitoring Nucl Med Commun 1992 13:127 136 1557210
50 Jabbari B, Van Nostrand D, Gunderson CH, et al. EEG and neuroimaging localization in partial epilepsy Electroencephalogr Clin Neurophysiol 1991 79:108 113 1713823
51 Duncan R, Patterson J, Hadley DM, et al. Tc99m HM-PAO single photon emission computed tomography in temporal lobe epilepsy Acta Neurol Scand 1990 81:287 293 2360394
52 Cordes M, Christe W, Henkes H, et al. Focal epilepsies: HM-PAO SPECT compared with CT, MR, and EEG J Comput Assist Tomogr 1990 14:402 409 2110581
53 Duncan R, Patterson J, Hadley DM, et al. CT, MR, and SPECT imaging in temporal lobe epilepsy J Neurol Neurosurg Psychiatry 1990 53:11 15 2303825
54 Kawamura M, Murase K, Kimura H, et al. Single photon emission computed tomography (SPECT) using N-isopropyl-p-(123I) iodoamphetamine (IMP) in the evaluation of patients with epileptic seizures Eur J Nucl Med 1990 16:285 292 2112471
55 LaManna MM, Sussman NM, Hamer RN, et al. Initial experience with SPECT imaging of the brain using I-123 p-iodoamphetamine in focal epilepsy Clin Nucl Med 1989 14:428 430 2501051
56 Mitsuyoshi I, Tamaki K, Okuno T, et al. Regional cerebral blood flow in diagnosis of childhood onset partial epilepsy Brain Dev 1993 15:97 102 8214339
57 Lee BI, Markand ON, Wellman HN, et al. HIPDM-SPECT in patients with medically intractable complex partial seizures Arch Neurol 1988 45:397 402 3258513
58 Stefan H, Kuhnen C, Biersack HJ, et al. Initial experience with 99m Tc-hexamethyl-propylene amine oxime (HM-PAO) single photon emission computed tomography (SPECT) in patients with focal epilepsy Epilepsy Res 1987 1:134 138 3143547
59 Marks DA, Katz A, Hoffer P, et al. Localization of extratemporal epileptic foci during ictal single photon emission computed tomography Ann Neurol 1992 31:250 255 1637133
60 Newton MR, Berkovic SF, Austin MC, et al. Postictal switch in blood flow distribution and temporal lobe seizures J Neurol Neurosurg Psychiatry 1992 55:891 894 1431952
61 Rowe CC, Berkovic SF, Austin MC, et al. Patterns of postictal cerebral blood flow in temporal lobe epilepsy: Qualitative and quantitative analysis Neurology 1991 41:1096 1103 2067640
62 Heinz R, Ferris J, Lee EK, et al. MR and positron emission tomography in the diagnosis of surgically correctable temporal lobe epilepsy AJNR Am J Neuroradiol 1994 15:1341 1348 7976947
63 Olson DM, Chugani HT, Shewmon DA, et al. Electrocorticographic confirmation of focal positron emission tomographic abnormalities in children with intractable epilepsy Epilepsia 1990 31:731 739 2245803
64 Markand ON, Shen W, Park HM, et al. Single photon imaging computed tomography (SPECT) for localization of epileptogenic focus in patients with intractable complex partial seizures Epilepsy Res Suppl 1992 5:121 126 1418440
65 Adams C, Hwang PA, Gilday DL, et al. Comparison of SPECT, EEG, CT, MRI, and pathology in partial epilepsy Pediatr Neurol 1992 8:97 103 1580967
66 Stefan H, Schneider S, Feistel H, et al. Ictal and interictal activity in partial epilepsy recorded with multichannel magnetoelectroencephalography: Correlation of electroencephalography/electrocorticography, magnetic resonance imaging, single photon emission computed tomography, and positron emission tomography findings Epilepsia 1992 33:874 887 1396430
67 Mazziotta JC. Practical clinical applications of positron emission tomography in epilepsy Am J Physiol Imaging 1988 3:28 29 3260501
68 Sperling MR, Alavi A, Reivich M, et al. False lateralization of temporal lobe epilepsy with FDG positron emission tomography Epilepsia 1995 36:722 727 7555991
69 Levesque M, Harkness W, Sutherling W, et al. SEEG localization in epileptic patients who fail localization after noninvasive studies Epilepsia 1992 33(Suppl 3):90 91
70 Snead OC 3d, Nelson MD Jr. PET does not eliminate need for extraoperative, intracranial monitoring in pediatric epilepsy surgery Pediatr Neurol 1993 9:409 411 8292221
71 Cross JH, Gordon I, Jackson GD, et al. Children with intractable focal epilepsy: Ictal and interictal 99TcM-HMPAO SPECT Develop Med Child Neurol 1995 37:673 681 7672464