# Diagnosis and Treatment of Impotence

Health Technology Assessment Reports, 1990 Number 2

## Foreword

The Office of Health Technology Assessment (OHTA) evaluates the safety and effectiveness of new or unestablished medical technologies that are being considered for coverage under Medicare. These assessments are performed at the request of the Health Care Financing Administration (HCFA). They are the basis for recommendations to HCFA regarding coverage policy decisions under Medicare.

Questions about Medicare coverage for certain health care technologies are directed to HCFA by such interested parties as insurers, manufacturers, Medicare contractors, and practitioners. Those questions of a medical, scientific, or technical nature are formally referred to OHTA for assessment.

OHTA's assessment process includes a comprehensive review of the medical literature and emphasizes broad and open participation from within and outside the Federal Government. A range of expert advice is obtained by widely publicizing the plans for conducting the assessment through publication of an announcement in the Federal Register and solicitation of input from Federal agencies, medical specialty societies, insurers, and manufacturers. The involvement of these experts helps assure inclusion of the experienced and varying viewpoints needed to round out the data derived from individual scientific studies in the medical literature.

After OHTA receives information from experts and the scientific literature, the results are analyzed and synthesized into an assessment report. Each report represents a detailed analysis of the safety, clinical effectiveness, and uses of new or unestablished medical technologies considered for Medicare coverage. These Health Technology Assessment Reports form the basis for the Public Health Service recommendations to HCFA and are disseminated widely. Individual reports are available to the public once HCFA has made a coverage decision regarding the subject technology.

OHTA is part of the Agency for Health Care Policy and Research (AHCPR), Public Health Service, Department of Health and Human Services.

- Thomas V. Holohan, M.D.
- Director
- Office of Health Technology Assessment
- J. Jarrett Clinton, M.D.
- Acting Administrator
- Assistant Surgeon General
- Copies may be obtained at no charge from:
- Publications and Information Branch
- AHCPR
- 5600 Fishers Lane
- Parklawn Building, Room 18-12
- Rockville, MD 20857; (301) 443-4100

## Introduction

Impotence has been defined as the inability to attain and maintain an erection sufficient to permit satisfactory intercourse or masturbation, or more commonly defined as consistent difficulty with erections in intercourse (1-3). Sufficient, in this context, has been described (but not supported by data) as penile tumescence and rigidity that exceeds 80 percent of erectile capacity in at least 75 percent of occasions (4). Impotence has also been defined as the inability to become physically aroused as a consequence of erotic stimulation (physical, mental, or visual) (5).

Although the ability to achieve erections is regarded as a normal phenomenon at any age, impotence is especially prevalent among older men and tends to occur in association with, or be a symptom of, other medical disorders such as diabetes, cardiovascular disease, uremia, or prior pelvic surgery (1,6,7). The incidence of impotence is estimated to be 17 per 100,000 man-years and affects 8-10 million adult males in the United States alone (8,9). In older men its incidence is estimated to be 25 percent at age 65,55 percent at age 75, and 75 percent at age 80 (10).

Contrary to the previous, widely taught, and popularly believed doctrine that most cases of impotence are primarily psychosomatic in origin, recent estimates derived from a variety of techniques developed to assess erectile dysfunction suggest that organic factors play a major role in 80-90 percent of cases, and psychogenic factors are a primary cause of impotence in only 10 percent of cases (1,11-13). As recently as 1984, the incidence of organic impotence was frequently estimated to be only in the range of 5-10 percent (14). Many cases of impotence involve both organic and psychogenic factors, with one or the other predominant, and there is general agreement that psychogenic impotence is caused by an interaction of psychological and physiological factors (15,16).

The differentiation between organic and psychogenic impotence has traditionally been the focus of diagnostic efforts. The diagnosis of psychogenic impotence was commonly made on the basis of the exclusion of organic factors (3,17). Interventions for psychogenic impotence will not be formally addressed in this assessment. For the majority of cases of organic impotence the traditional treatment (for the past 20 years) has been an implantable penile prosthesis (3,18). The prosthesis has been successful in achieving satisfactory results in 80-90 percent of selected patients (12,19,20). Both inflatable and noninflatable devices are regarded as being safe, reliable, and effective by the Food and Drug Administration (FDA) and will not be formally addressed in this assessment (18,21).

As the number of therapeutic options for the treatment of impotence has increased, the need for a more accurate diagnosis has become an essential prerequisite for the selection of optimal treatment. In one series of cases, a specific organic etiologic diagnosis was possible in 95 percent of patients (17). However, pure cases of either organic or psychogenic impotence are uncommon, and the precise etiology for the majority of cases remains unknown (22-25). A multifactorial etiology is thought to exist in impotence, and the need for a unified multi-disciplinary and comprehensive approach to evaluate and treat this disorder has been stressed by many investigators (23,24).

A universal etiologic classification of impotence does not exist. However, impotence has been commonly classified as being organic, psychogenic, or having an unknown etiology (3,18). A recent review of five major studies of the etiology of impotence concluded that most impotence has an organic basis, with diabetes and other endocrinopathies being the most common causes. The most common cause of nonorganic impotence was found to be drug effects (including alcohol). These findings are summarized in the table. In patients over the age of 50, approximately 50 percent have a vascular cause for their impotence, and in patients with peripheral artery disease requiring aortoiliac reconstructions, 70-80 percent are impotent (25,26).

Diabetes-associated impotence (not related to the severity of disease or the degree of control) has been attributed to both vascular and neurologic factors, and is reported to have an incidence of 15 percent at ages 30-40 and 55 percent at age 60 (14,27). As seen in the Table 1, there is a wide range (6-45 percent) in the reported incidence of endocrinopathies clearly contributing to impotence. Other studies have concluded that endocrinopathies are a relatively uncommon cause of impotence and report a frequency of only 2-5 percent (3,28-30).

Table 1. Causes of impotence by system or disorder

System/disorder | Percent [*] | Example
Endocrine | 6-45 | Hypogonadism, thyroid dysfunction, hyperprolactinemia, diabetes, abnormal glucose tolerance test
Vascular | 1-37 | Leriche syndrome, iliac artery obstruction
Urologic | 6-49 | Prostatitis, urethritis, Peyronie's disease, uremia
Neurologic | 2-8 | Spinal cord compression, multiple sclerosis, traumatic injury to spinal cord, postsurgical complications (pelvic)
Other systemic disease | 2-6 | Hepatic failure
Other; - Alcoholism; - Drug side effects | - 1-7; - 2-25 | -- Diuretics, antihypertensives, tranquilizers
Psychogenic | 14-16 | Depression, neuroses
Unknown | 1-19

* The wide range in some of the percentages can be explained, in part, by selection and referral biases.

Normal gonadal function is a complex process involving the hypothalamus, the pituitary, and the gonads. It may be disrupted by a variety of primary diseases (pituitary adenomas or Klinefelter's syndrome) or the systemic effects of such diseases as renal failure, hepatic failure, diabetes, sickle-cell disease, thyroid dysfunction, or malnutrition (31). The endocrinopathies most commonly associated with impotence are hyperprolactinemia (related to medications or pituitary tumors) and hypergonadotropic or hypogonadotropic hypogonadism (15). Hypogonadism, the most common impotence-related endocrinopathy, has been reported in up to 20 percent of patients over age 50 (1,12). Of these patients, 33-50 percent have primary testicular failure; the remainder exhibit some form of hypothalamic-pituitary dysfunction resulting in elevated prolactin levels causing impotence by inhibiting testosterone action (1,20). The vast majority of patients with organic impotence have a vascular or neurologic basis for their problem (15,32). In an evaluation of 1,500 consecutively examined patients with impotence, a central or peripheral neurogenic component contributed to the disorder in almost 20 percent of cases (31). Although the precise mechanisms involved in the erection process remain undefined and controversial, the ability to achieve and sustain a normal erection is dependent upon a complex and coordinated interaction of vascular, neurologic, hormonal, psychological, and interstitial factors (1,29,32,33). Impotence may result from dysfunction of any one or a combination of these systems (21).

The penis is composed of three parallel cylinders enclosed by an outer sheath of firm inelastic fascia (tunica albuginea) (34). The two major cylinders (corpora cavernosa) extend from the ischial tuberosity to the glans. The minor cylinder (corpus spongiosum) surrounds the urethra. These corpora, which are the erectile tissues of the penis, consist of a network of loosely interlaced smooth muscle-lined sinusoidal spaces (35). When the penis is flaccid, there is a resting adrenergic tone that maintains the intracorporeal pressure at 5-10 mm Hg. During sexual (erotic) stimulation, the nervous system responds with an increased parasympathetic outflow, inhibiting the adrenergic (sympathetic) tone of the arteriolar and sinusoidal smooth muscles. This reduces the resistance to blood flow, leading to a shunting of blood into the corpora via arterial venous networks, expansion of the sinusoidal spaces (lacunae), distension of the tunica albuginea, and compression of the venules and emissary veins that effect a decrease in the venous outflow (2,36). Intracorporeal pressure rises until it equals the mean arterial pressure. This increased pressure within the corpora is manifested by penile erection. These hemodynamic changes associated with the erectile process are mediated by endogenous neurotransmitters (38). Eventual detumescence is usually a consequence of increased sympathetic vasoconstrictor activity causing a decrease of blood flow into the corpora. Nocturnal erections are normal, nonsexually stimulated erections and presumed to be the result of the release of tonic inhibitory central nervous system activity. However, the precise mechanism responsible for this phenomenon remains unknown (38).

### Diagnosis

The approach to evaluating erectile dysfunction impotence) continues to be both controversial and varied, with emphasis on identifying etiologies in patients who might benefit from specific therapies. The multifactorial etiology for most cases of impotence makes it unlikely that individual indices of erectile dysfunction will establish an etiologic diagnosis, and an accurate diagnosis will require a comprehensive multidisciplinary assessment of these patients (39,40). The evaluation of impotence is handicapped by the absence of universally accepted and validated objective measures of erectile function that correlate with sexual ability, and appropriate testing for diagnosis remains controversial (3). Nevertheless, evaluation procedures have evolved from clinical experience and include physical and psychological examinations, endocrine assessment by hormonal assays, evaluation of the competence of penile circulation, electrophysiological testing of neurologic competence, and nocturnal penile tumescence (NPT) testing (3,11,38,41).

## Review of Available Information

### Monitoring of nocturnal penile tumescence

It has been widely accepted in the past that patients with predominantly psychogenic impotence will regularly attain normal erections during rapid-eye-movement (REM) sleep, while patients with organic impotence will not demonstrate significant sleep-associated normal erections (42). The normal pattern of erections during sleep (between ages 3 and 79) are episodes occurring approximately every 85 minutes and lasting approximately 25 minutes. The total duration of erection time diminishes and the latency period between erections increases with aging (43). Until 1980, NPT testing was regarded as the only objective technique for the differential diagnosis of organic versus psychogenic impotence (43,44). Its major disadvantages are that it does not quantify penile rigidity, it depends on adequate REM sleep, and it lacks standardization among laboratories (20,43).

During NPT testing, mercury strain gauges placed on the shaft of the penis can detect and measure changes in penile circumference during sleep. An increased circumferential expansion of the penis does not necessarily correlate with adequate rigidity of sufficient duration required for normal intercourse (41,45). However, adequate and sufficient in this context has not been satisfactorily defined (42). During episodes of maximal tumescence (measured on an electroencephalographic tracing), penile rigidity can be measured by a rigidometer. Rigidity is a consequence of sufficient intracorporeal pressure rather than functionally related to changes in penile circumference (38). A commercial rigidometer is available for continuous and simultaneous monitoring of penile rigidity and circumferential expansion (45). The device consists of recording loops applied to the base and tip of the penis that are connected to a sensor able to measure and record data on rigidity and circumferential change for periods of up to 10 hours (45). Testing is commonly performed during three consecutive nights.

A normal result of NPT, measured with strain gauges, is two or more periods of sustained erections lasting more than 20 minutes and associated with at least a 25-mm increase in penile circumference (3). Normal NPT in a person with sexual dysfunction implies intact neurovascular structures and suggests psychogenic impotence (3). An abnormal recording only suggests organic impotence, which will then require further testing for a more definitive diagnosis (38). Nocturnal penile tumescence testing has an accuracy of 85-90 percent in measuring erectile capacity but can have a high incidence (15-20) of false-positive results (5,47). False-negative findings (not as common) can be seen with sensory neuropathies, pelvic steal, and corporeal leakage syndromes (17). The accuracy of NPT testing can be increased when it is combined with both visual inspection and rigidity determinations (48). In a study of 105 patients with impotence, Kaneko and Bradley demonstrated that rigidity measurements enabled a change of their initial diagnosis from psychogenic to organic in 3 of 11 cases (27), and from organic to psychogenic in 7 of 94 cases (7.4) (46). Some patients have been shown to achieve normal erections during their waking hours but remain flaccid during sleep. Awake erections have been regarded as a better reflection of sexual function than NPT testing (22,49).

Approximately 20 percent of subjects with impaired NPT have no demonstrable organic disease (16,37). Another 20 percent of patients with normal NPT have insufficient rigidity (11). These facts suggest subclinical physiologic deficits and/or psychogenic factors related to impotence. Nocturnal penile tumescence testing performed in a sleep laboratory with polysomnography (which measures the quality and quantity of REM sleep and other physiological variables) offers a noninvasive approach to the differential diagnosis of impotence. However, the value of NPT measurements in sleep laboratories has not been validated in large groups of patients (11,38). In addition, the criteria that will provide the maximum diagnostic accuracy of the NPT testing variables used to differentiate organic from psychogenic impotence have not been established (50). There is a need to continue the process of validating the sensitivity, specificity, and efficiency of NPT testing (51,52).

A common problem affecting the interpretation of NPT test data is the great variation in circumferential increase among normal subjects that makes it difficult to determine the significance of the maximum circumferential increase in individual patients. In an attempt to obviate this problem, Morales et al have devised a procedure, the corporeal calibration test (used as a complement to conventional NPT tests), that measures the circumferential size required to produce a rigid penis (4). The test involves the production of an artificial erection by the infusion of saline into the penile corpora and recording the increases in circumference with a mercury strain gauge placed behind the penile corona (at the same site as during NPT testing) and connected to a plethysmograph. Although NPT testing, especially with a rigidometer, can provide objective data, some investigators suggest that direct observation to confirm the quality of erections is necessary for the diagnosis of impotence (16,53). In one study, 37 percent of normal subjects were unable to achieve a full erection under laboratory conditions (54). In addition to the use of mercury strain gauges or a rigidometer, NPT testing has been monitored by other techniques including the postage stamp test, Poten Test, and Snap-Gauge. These techniques have been devised as simple, inexpensive screening devices for inhome self-testing. However, these devices provide no satisfactory indication of rigidity and duration of tumescence, regarded by many investigators as a necessary component in the evaluation of impotence.

The postage stamp test involves the use of unperforated postage stamps measuring 1 by 1.5 inches that are wrapped around and pasted on the flaccid penis at bed-time. If upon awakening the stamps are broken along the perforation, a good erection is presumed to have occurred (38). Although no breakage can suggest organic dysfunction, breakage cannot lead to a diagnostic conclusion, and the test, therefore, has limited diagnostic value (55). Despite the fact that the stamp test frequently yields unreliable results relative to NPT, its low cost and simplicity has led to its use by some investigators as a screening device (56-58). The Poten Test is a standardized, commercially available stamp test that has essentially the same advantages and disadvantages of postage stamp testing (59).

The Snap-Gauge was introduced by Ek, Bradley, and Krane as a screening device to detect nocturnal erections (60). The device was designed to measure both circumferential expansion and rigidity (radial stiffness) (57). Some investigators reserve the Snap-Gauge for patients with an equivocal or positive stamp test result (24). The gauge consists of three pliofilm elements, each a different color, embedded in a band encircling the flaccid penile shaft (60). The elements have different release constants set at 26 g, 340 g, and 453 g of force (61). The band is adjustable and fastened around the penis using a self-adhesive strip. During tumescence, one, two, or three of the pliofilm elements may break, depending on the degree of pressure from the engorged penis, which thus provides a quantitative estimate of rigidity (60). If two or three bands break, nonorganic impotence is suspected. If none or only one breaks, the problem is more likely to be organic (61). However, the relationship between the breakage of particular elements and a specific diagnosis has not been established, and in general, the value of any diagnostic technique based solely on circumferential measurements must be questioned (57). In a study of 41 patients consecutively evaluated with both Snap-Gauge and a rigidometer, Bradley demonstrated equal agreement on the diagnosis of impotence with either device; however, a more precise definition of the abnormality was described by using the rigidometer (62).

Despite their shortcomings, inhome monitoring devices designed to measure tumescence and/or rigidity have been regarded by some investigators as reasonable screening procedures, especially when sleep laboratory facilities are not readily available or feasible (63). In an evaluation of the reliability of NPT monitoring, Condra et al found discrepancies and inconsistencies between penile brachial index (PBI) testing and other diagnostic tests for impotence and little agreement between NPT records and patient-partner self-reports (64). These investigators concluded that NPT was not a reliable index for evaluating impotence.

### Penile vascular assessment

Because vasculogenic factors play such a prominent role in the pathogenesis of impotence and to a large extent are regarded as amenable to treatment interventions, penile vascular assessments have occupied a significant portion of the time and attention of investigators. In a series of 353 patients screened for neurologic, arterial, and venous components of impotence, vascular pathology was found to be the major cause (32). According to the National Institutes of Health (NIH), in a communication to the Office of Health Technology Assessment (OHTA), disruption of penile arterial flow and venous leakage from the corpora are the most frequent causes of organic impotence, affecting approximately 5 million men in the United States.

In addition to NPT testing, which is a nonspecific indicator of vascular competence (26). , evaluation of the functional status of the penile vasculature has been done by arteriography, ultrasonography, cavernosography, cavernosometry, and spectroscopy, as well as through evaluation of radioactive washout, determination of the PBI, response to intracorporeal injections of vasoactive drugs, temperature measurement, and the results of the hyperemic stress test (11,26,38,65).

Arteriography is an established technique used as a definitive diagnostic procedure for arterial spasm or occlusion as a cause for impotence when other noninvasive diagnostic measures have failed. The procedure involves the injection of contrast material into the internal iliac or internal pudendal arteries, or directly into the penile corpora. The procedure is painful and requires general or regional anesthesia and is associated with a considerable risk of morbidity. Generally, arteriography is reserved for those patients suspected of having isolated arterial disease or considered for surgical revascularization (11,20). In a prospective controlled trial of arteriography in 40 impotent subjects, both positive and negative results clearly agreed with findings from PBI (described below) during exercise (66).

Penile blood pressure measurements by Doppler ultrasound pulse-wave analysis or less commonly by strain-gauge plethysmography are the most frequently used techniques in evaluating vasculogenic impotence (20,45). Doppler ultrasound measurements are confined to a single vessel and are difficult to perform in the distal portion of the penis. They also give no information about cavernous arterial flow (47,66). On the other hand, plethysmography, involving complex equipment and numerous practical problems, measures blood flow in all the vessels in a cross-section of the penis, with results regarded as superior to those derived from Doppler measurements (20,67). In a study by Doyle and Yu comparing plethysmography with Doppler ultrasound in 61 patients, plethysmography was found to be more rapid and reliable and had a sensitivity, accuracy, and specificity of 93, 95, and 100 percent respectively (68). However, the relative ease, accuracy, and noninvasive nature of Doppler pulse-wave analysis have prompted many investigators to prefer its use over both impedance and mercury strain-gauge plethysmography for the evaluation of penile circulation (69-71).

In a double-blind controlled clinical trial comparing direct penile ultrasound (to detect intracavernous fibrosis) with NPT testing and penile blood pressure measurements in 88 impotent patients and 30 normal controls, ultrasound was found to correlate significantly with plethysmography when performed and evaluated by a skilled physician (71). These investigators advocated the use of ultrasound as a rapid, inexpensive, noninvasive screening method for classifying vasculogenic versus psychogenic or neurogenic impotence. A spectroscopic method of measuring systolic blood pressure adapted to the penis was described by Gaskell in 1971 but apparently has been abandoned (65).

The penile blood pressure by Doppler compared with the brachial blood pressure both at rest and after exercise yields the PBI. A ratio of less than 0.75 is suggestive of, and a ratio of less than 0.6 is considered diagnostic of, vasculogenic impotence (26,35). Patients with a steal syndrome exhibit a decrease in penile blood pressure by a diversion of the penile blood supply during and immediately after exercise (12,72). In a study of 216 impotent men aged 40-79, Kaiser et al found that 23 percent of the abnormal PBI findings were seen only after exercise (26). In a prospective study of 503 patients with organic impotence. Chiu et al found the predictive power of ultrasonically derived PBI was best demonstrated in patients with peripheral vascular disease (73). Penile brachial index findings have also been correlated with arteriographic findings in studies of impotent men (66).

In individuals who are not clearly impotent and whose PBI ratios range between 0.7 and 0.8, a hyperemic stress test has been devised for determining whether or not these ratios are indicative of vasculogenic impotence (74). This test is based on the principal of postocclusive hyperemia used in testing peripheral arterial vasculature. Systolic occlusion pressure of the dorsal penile artery is measured by means of a 1-inch sphygmomanometer cuff with a 9. 4 mm Hg Doppler probe. The penile cuff is inflated 10-15 percent above the systolic pressure, maintained for 5 minutes, and then rapidly deflated. Potent patients responded to this stress with an elevation of penile pressure by a factor of 20 percent, while impotent patients demonstrated no increase or decrease in pressure. Patients with increased flow demonstrate erythema of the penile skin. This postocclusive hyperemia is an expected response in patients with normal arterial flow and occurs within 60 seconds of releasing the occlusion. Patients with compromised arterial flow exhibit an absence or delay of the hyperemia.

Penile temperature measurement using either an electrothermometer or thermography is another noninvasive way to determine arterial flow (17,75). However, temperature measurement is subject to significant error and has not had its reliability as a screening test confirmed.

Since 1982, the use of vasoactive drugs injected into the penile corpora has been widely used as a simple screening technique for the differential diagnosis of vasculogenic impotence (45,76). Prior to the advent of this technique, the differentiation of organic from psychogenic impotence involved extensive time-consuming testing. Six groups of drugs having smooth muscle relaxing properties have been demonstrated to induce erections when injected intracorporally (76). These are: alpha-adrenergic blockers, beta agonists, smooth muscle relaxants, calcium channel blockers, antidepressants, and peptides.

The nonspecific smooth muscle relaxant, papaverine, is the most widely used agent for inducing erections. Although its precise mechanism of action is unknown, its alpha-adrenergic blocking effect induces arterial dilation, sinusoidal relaxation, and partial venous occlusion when injected into the penile corpora in patients with intact arterial and venous functions (77,78). The relaxation of the smooth muscle lining of the sinusoidal channels of the corpora permits engorgement of the erectile bodies with blood and the consequent erection. These hemodynamic changes are similar to those induced by neurostimulation causing spontaneous erections (76). Papaverine, 30-60 mg, injected into the penile corpora will generally induce a firm erection within l5-10 minutes, lasting 30-45 minutes (79,80). A full erection following the use of an intracorporeal injection excludes the presence of severe arterial insufficiency or substantial cavernous leakage (81). If a papaverine test is positive in an impotent patient, further testing, probably of NPT, may be required to differentiate neurogenic from psychogenic impotence. The failure to respond with an erection to a test dose of papaverine suggests significant vascular disease (76,79). An incomplete erection or rapid detumescence following a firm erection is suggestive of venous incompetence (67,79). However, a definite diagnosis of cavernosal leakage requires cavernosography, usually with cavernosometry (20).

In a current, ongoing trial of intracavernosal injections in the differential diagnosis of impotence (115 patients to date) it has been possible to differentiate nonvascular, arterial, and venous etiologies (80). A response to the smallest dose indicated nonvascular impotence. No response to the highest dose indicated venous insufficiency. However, in an earlier trial of 144 impotent patients with various etiologies (psychogenic and organic), Robinette and Moffat concluded that the high response rate (97) to the intracorporeal injection of a papaverine-phentolamine combination precluded its usefulness in differentiating between types of impotence (82).

Strachan and Pryor used intracavernosal papaverine in 129 patients in an attempt to differentiate vasculogenic from psychogenic impotence (83). They noted an age-related drop in response rate ranging from 86 percent at ages 18-29 to 15 percent at ages 60-71. They also reported that results of intracavernosal papaverine testing agreed with the results of NPT testing in 68 percent of cases. Abber et al compared papaverine injections with PBI and NPT testing and concluded that intracavernosal papaverine was superior to those other methods for the diagnosis of vasculogenic impotence (84).

Mellinger et al examined the correlation between Doppler analyses and papaverine injections in 100 impotent men (79). They found normal Doppler analyses failed to predict a lack of response to papaverine in 54 percent of subjects. However, abnormal Doppler analyses were highly predictive of a vascular abnormality. In the evaluation of vasculogenic impotence many investigators combine Doppler ultrasound with intracorporeal injections of papaverine to increase the diagnostic accuracy (67,79). Finally, studies of organic impotence using induced erections in aging men (up to age 85) have found a leakage factor in the corporal cavernosa to be the most frequent cause of erectile failure (77,79,85).

Cavernosography and cavernosometry are essential techniques to specifically identify the type of cavernosal leakage (86,87). Conventional cavernosography is the isolated x-ray visualization of the cavernous bodies and their venous drainage by means of contrast material. This procedure can detect scar tissue, abnormal vascularity, and specific venous leaks or shunts. Dynamic cavernosography consists of a cine-taped cavernosogram in conjunction with intracavernous pressure measurements (cavernosometry) at three different saline infusion rates into a single corpus to achieve an erection. An accurate determination is made of the flow rate and pressure within the cavernous bodies (87). A normal response is an erection at a pressure of approximately 20 mm Hg. No erection or tumescence at any flow rate is regarded as diagnostic of a venous leakage problem. Higher flow rates are seen in patients with significant venous drainage abnormalities. In patients with normal erections, no outflow of contrast material into penile or pelvic veins can be seen on x-ray.

In a study of these combined techniques in 122 impotent patients and 18 normal patients used as controls, Porst et al found that 54 percent of the impotent patients exhibited venous leakage (88). Forty-four percent of this group had isolated dorsal penile vein insufficiency and 32 percent had complex venous leakage. These investigators then compared the results of papaverine injections in 63 of these impotent patients to those of dynamic cavernosography and found papaverine injection provided a sensitivity of more than 90 percent in the diagnosis or exclusion of a hemodynamically relevant venous insufficiency. However, this was obtained only in cases having a clear-cut test result. Papaverine testing was not reliable in cases of incomplete erections, although it remained useful as a screening procedure.

The evaluation of both arterial and venous penile blood flow can also be determined by injecting radioactive (133)Xenon (Xe) into one corpus and measuring its washout (45,89). This technique is rapid, minimally invasive, reproducible, and a direct measure of penile blood flow (rather than indirectly via Doppler or plethysmography). It is regarded as potentially superior to other standard techniques as a screening test for vasculogenic impotence (1,20). However, conflicting results have been reported by other investigators using (133)Xe in evaluating penile blood flow in human volunteers viewing erotic films (76).

### Neurological Assessment

In addition to NPT and penile vascular assessment methods, neurological assessments can assist in the evaluation of the degree and nature of organic impotence. Although the erectile process is primarily a vascular phenomenon, it is mediated by complex neural mechanisms involving the sacral reflexogenic erection center (parasympathetic) and the thoracolumbar psychogenic erection center (sympathetic) (90). Interruption of any of these pathways can result in impotence (32).

Nerve conduction studies including the bulbocavernous reflex latency time and the internal pudendal nerve-evoked potentials can detect abnormalities in the function of the pelvic nerves supplying the penis (11,20). Bulbocavernosal reflex testing has been shown to be useful in evaluating patients suspected of having impotence related to cord lesions at the sacral level or pudendal neuropathy (17,32). However, this reflex test is insensitive, being present in only 70-80 percent of potent men. The reflex is elicited by stimulation of the penile glans, and the response is contraction of both the bulbocavernosal muscles and the external anal sphincter. Measurement of pudendal nerve velocity can be used to quantify the reflex. In a study of 52 men with electrophysiologic testing of this reflex, excellent correlation was obtained between prolonged latency and clinical evidence of neuropathy (91). Of the 17 patients who were evaluated for impotence, 10 had normal physical examination findings and were believed to have psychogenic impotence. Of the remaining seven, four had diabetes mellitus, one had prior pelvic surgery, one had cauda equina syndrome, and one had a history of exposure to toxic chemicals. After a study of the bulbocavernosal reflex in 100 consecutive patients with erectile dysfunction, Wabrek concluded that reflex testing needs to be done when penile revascularization is considered as a therapeutic option (92). An abnormal latency would contraindicate revascularization.

An objective and direct neurophysiologic assessment of the entire pudendal nerve afferent pathway (including the dorsal penile nerve) may be obtained by evoked-potential testing and penile biothesiometry (32). The evoked-potential testing involves electrical stimulation of the dorsal penile nerve in a manner similar to that used in testing the bulbocavernosal reflex but recording the evoked-potential electroencephalographic waveforms overlying the sacral region of the spinal cord and cerebral cortex, rather than the electromyographic response seen in the bulbocavernosal test. This test is most useful as a measurement of the presence, location, and nature of penile sensory dysfunction.

As another sensory screening test, penile biothesiometry measures the vibration perception threshold of the skin of the penis using a handled electromagnetic vibration device having a fixed frequency but variable amplitude of vibration. The test is performed by asking the patient to respond to the first sensation of vibration as the device is placed against the lateral shaft and glans of the penis as the amplitude of vibration is slowly increased (17). In a study of 137 patients with organic impotence tested with both biothesiometry and subsequent sensory evoked potential testing, 80 percent of the 38 patients who had a normal biothesiometric examination had normal evoked-potential testing (32). This increased to 93 percent for those under age 60. Ninety-nine patients had an abnormal biothesiometric result, 47 percent of whom also had an abnormal evoked-potential test. The majority of patients with erectile dysfunction related to a sensory deficit were subsequently found to have an underlying diabetic or alcoholic neuropathy. Using this same study design with another group of more than 500 patients, abnormal biothesiometric values were seen in 23 percent, 50 percent of whom had an abnormal evoked-potential test that was highly correlated with neurologic disease. A normal evoked-potential test in patients with abnormal biothesiometry results suggests vascular insufficiency of the somatosensory receptor cells or collagen infiltration of the penile skin (93). These investigators concluded that penile sensation is most objectively measured by evoked-potential testing; however, it may be more simply assessed by biothesiometry.

In another recent study, skin potentials were recorded from the genitals and extremities of potent and impotent men (94). Fifty patients (10 psychogenically impotent, 32 impotent diabetics, and 8 potent diabetics) and a control group of normals were evaluated using an adapted skin potential recorder. More than 50 percent of the impotent diabetics had an abnormal recording. All others had normal recordings.

Since the detrusor mechanism of the bladder shares the same autonomic innervation as the erectile mechanisms of the penis, cystometric studies can also provide a measure of the integrity of the neural pathways (25).

Electrostimulation and electromyographic analyses have also been used in the diagnosis of impotence in patients with neurological problems (17). However, their use has not been studied in sufficient numbers of patients to be properly evaluated.

### Endocrine assessment

Endocrine evaluation in impotent men includes the determination of serum levels of testosterone, prolactin, follicle stimulating hormone, and luteinizing hormone (15,20). Testosterone levels are frequently measured alone, and other hormonal levels are measured only if testosterone levels are reduced (22). However, some patients with impotence associated with hyperprolactinemia do not exhibit reduced testosterone levels (95).

Although hormone changes may contribute to diminished libido, reduced sexual function, and ejaculation dysfunction, they generally do not cause impotence (28,96). However, there continues to be a wide range in the reported incidence of impotence associated with endocrine abnormalities. In one study, a screening of 105 consecutive impotent patients found 37 (35) with previously unsuspected endocrine disorders involving the hypothalamic-pituitary-gonadal axis (13). Another study of 300 impotent men screened by testosterone and prolactin assays detected endrocrine dysfunction in only five patients (1.7) (29).

Patients on chronic hemodialysis often exhibit impotence, which is thought to be related to increase blood levels of prolactin (97). In addition, it has been demonstrated that zinc deficiency, commonly associated with uremia, is a major cause of abnormalities in testosterone synthesis and metabolism (98).

### Treatment

The therapeutic modalities that have been applied to the management of impotence include psychotherapy, vascular surgery, prosthetic devices (external or implanted), intracavernosal injections, and hormonal and other drug therapies. Psychotherapy, in the case of psychogenic impotence, and the insertion of penile implants for organic impotence have until recently been primary treatments (11,99). However, as mentioned earlier, review of these treatments are beyond the scope of this assessment and will not be addressed here. Because the vast majority of organic impotence is of vascular or neurogenic etiology, surgery (revascularization or prosthetic) has been the most widely used form of therapy. More recently, the use of intracavernosal injections of vasoactive drugs has garnered the most interest and attention in the treatment of impotence.

### Revascularization

Vascular surgery for the treatment of impotence involves either surgical or microsurgical arterial bypass procedures or surgery involving the venous drainage of the penis. These procedures have been shown to restore potency in selected patients with vasculogenic impotence (18,100,101).

A variety of surgical techniques have been proposed to treat vasculogenic impotence. Aortoiliac reconstruction, endarterectomy, or arterial dilators have been successful in treating proximal occlusive lesions (Leriche syndrome). In a series of 38 patients with Leriche syndrome, 27 (71) were functionally impotent preoperatively (102). Postoperatively, an increased penile pressure was noted in 14 patients (37), a decrease was seen in 8 patients (21), and no change occurred in 16 patients (42). In the 27 patients who were preoperatively impotent, increased penile pressure was associated with restored potency in 8 of 11 patients. Only 1 of the 10 patients with unchanged penile pressure regained potency. For distal lesions, femoral or inferior epigastric blood can be directed to the dorsal penile arteries or vein or directly to the corpora (103). However, patients having these procedures have generally had short followup, and bypass has been frequently followed by occlusion.

In 1982 Virag reported a success rate of nearly 50 percent with a series of cases involving arterialization of the deep dorsal vein (104). This procedure entails anastomosis of the inferior epigastric artery to the deep dorsal penile vein (105). Six variations of the procedure are described. In 1988 Bennett reported the results of 50 venous arterializations, in which 60 percent of the patients were able to resume sexual activity (106). Patients were followed from 1-3 years. Major complications occurred in three patients. One case of priapism and two cases of hypervascularization of the glans required ligation of the anastomosis resulting in failure of the procedure. Balko et al reported inconsistent results in patients followed for up to 20 months after deep penile vein arterialization for arterial impotence (107). Their procedure consisted of femoral artery to deep penile vein saphenous bypass.

Successful penile revascularization was first reported in 1973 and has had only limited success since that time (11,16). Success rates have ranged from 30-80 percent (20). Goldstein has reported success in approximately 70 percent of young patients with pelvic injuries treated by anastomosis of the inferior epigastric artery to the dorsal penile artery (108). Crespo et al reported their experience in the treatment of vasculogenic impotence using microvascular techniques involving the interposition of an autologous vein segment between the femoral artery and cavernous and/or dorsal arteries of the penis (103). They performed 95 bypasses in 45 impotent patients. Of their 22 patients who were seen for 6 months after surgery, 17 were cured, 3 improved, and 2 were unchanged. Pearl and McGhee reported a 60 percent long-term success rate using microsurgical arterial revascularization in the treatment of vasculogenic impotence (109). McDougal and Jeffrey described revascularization in eight impotent patients using bilateral anastomosis of the inferior epigastric arteries to the dorsal penile arteries (111). In a review of the status of penile artery revascularization, Shaw and Zorgniotti concluded that the best results were seen in younger patients. Older patients or those with diabetes or hypertention or patients who have had coronary bypass surgery do not appear to have good results (100).

Dynamic infusion cavernosometry and cavernosography studies have indicated that corporeal leakage exists in more than 80 percent of patients with organic impotence (111,112). Leakage is generally associated with an increase in both the number and size of the veins draining the corpora or abnormal shunting between the corpora and the glans (113). More than 50 percent of patients with venous leakage as a cause of impotence have insufficiency of the dorsal vein or ectopic penile veins, both of which are amenable to surgery (87).

The common surgical procedures for the treatment of venous leakage include dorsal vein resection either alone or combined with arterialization with or without pericavernous ligation (88). Arterialization procedures are best reserved for patients with mixed etiology, for example, arterial disease in addition to venous leakage (113). Ligation of the deep dorsal vein has resulted in improved sexual function in 50-75 percent of patients with venous incompetence (20,112). Wespes and Schulman reported correction of venous leakage via the deep dorsal vein by simple ligation of this vein (113). Sixteen of their 20 patients exhibited improved erections satisfactory for intercourse.

A recent review by Lewis of the results of venous dissection surgery in 549 selected patients with cavernous venous leakage indicated good to excellent results in the range of 19-73 percent reported at followup from 3-26 months (114). Those patients with poor surgical results were able to obtain satisfactory pharmacologically induced erections where this was not possible prior to surgery. In a study of eight patients who underwent deep penile vein arterialization combined with ligation of the superficial veins at the base of the penis, Balko et al reported that nocturnal tumescene was excellent in four patients with venous leakage and one of four patients with mixed factors (107). A novel treatment of venous leakage has been described by Courtheroux et al using detachable balloons and coils to embolize the deep dorsal vein of the penis (115). They treated 31 patients having venous leakage with the implantation of balloons and coils. Twenty-six of these patients recovered normal sexual function.

### Intracavernous injections

In addition to their use as a screening technique for the differential diagnosis of impotence, vasoactive drugs have been extensively applied as a therapeutic modality for impotence. Currently, the intracavernous injection of the nonspecific smooth muscle relaxant, papaverine, has become the most widely used pharmacologic agent in the treatment of impotence (15,116).

The concept of intracavernous injections of vasoactive substances was prompted independently by Virag in 1982 and Brindley in 1983. Virag used papaverine to induce erections and noted that this was followed in some cases by the ability to have spontaneous erections for variable lengths of time until a repeat injection was required (117). Brindley used the alpha-adrenergic blocker phenoxybenzamine (not available in the United States) to produce erections that were of unpredictable duration lasting between 30 minutes and 30 hours (81,118).

Papaverine, either alone or combined with the alpha blocker, phentolamine, has evolved as the favored agent worldwide for pharmacologically induced erections (15,119-121). However, a number of other agents including theophylline, prostaglandin E(1) (PGE(1)), nitroglycerine, and vasoactive intestinal polypeptide (VIP) can also induce erections (39).

Intracavernous injections of papaverine at doses of 5-120 mg commonly produce erections within 10 minutes (usually in less than 5 minutes) lasting from 30 minutes to 6 hours (20,119). Phentolamine, injected in doses of 2-4 mg, commonly produces tumescence but not full rigidity (as seen with papaverine), in the presence of organic impotence (33). The combination of papaverine plus phentolamine permits the use of reduced doses of both drugs and achieves a higher response rate with lessened morbidity (119).

The ability of vascoactive drugs injected intracavernously to induce erections satisfactory for intercourse has been confirmed in a large number of published reports. However, these drugs have no effect on the ability to achieve ejaculation or orgasm (39). The results are generally better in patients with psychogenic, hormonal, or neurogenic impotence and worse with vasculogenic impotence (20,122). However, patients with severe psychogenic problems may have a poor response because of increased blood levels of adrenaline (19). The effect of these injections may persist for up to 4 weeks, a phenomenon that has been difficult to explain (123).

Although the precise mechanism of action for injectable vasoactive drugs producing erections is unknown, the effects have been referred to as a pharmacologic angioplasty in patients with mild penile arterial insufficiency and also as a chemical prosthesis (18,20). It has been suggested by Sidi that the injection of vasoactive drugs mimics the action of endogenous neurotransmitters to induced penile erections (39).

Orvis and Lue, referring to a report of a double-blind crossover trial in which 29 percent of patients with organic impotence reported improved erections after saline injections, have suggested that psychological factors may play a role in the response of intracavernosal papaverine (18). Further trials using placebo injections were recommended.

A recent report has made the point that intracavernous injections do not result in erections but rather priapisms with the typical sign of the nonerected glans (124). Priapism is defined as an abnormal and persistent erection that does not subside after intercourse or masturbation. Typically it affects only the corpora cavernosa, not the corpus spongiosum or the glans (125).

In a 1986 review of the published experience with papaverine alone in 491 patients, and papaverine combined with phentolamine in 175 patients, response rates were seen in the range of 19-60 percent with papaverine alone and 81-95 percent with the combination (126). Papaverine alone yielded responses of 1-2 hours' duration. The combination required less dosage and produced longer-lasting erections. Proper responses were seen in patients with a long history of impotence, diabetes, hypertension, heart disease, or peripheral vascular disease. Adverse reactions included dizziness (7 cases); prolonged erections over 4 hours (83 cases); and local pain, ecchymosis, and hematoma (32 cases). In a series of 66 patients with impotence (as a consequence of spinal cord injury) treated with papaverine or papaverine/phentolamine, 52 achieved a good response, and 71 percent of this group continue to practice self-injection at home with relatively minor adverse reactions (127).

In a study of 100 consecutive patients treated with papaverine as a single agent, Lue and Tanagho reported 60 patients achieved improved sexual function for periods of 1-3 weeks before returning to the preinjection impotent state (128). Complications included transient local paresthesia, hematoma, infection, ecchymosis, priapism, and fibrosis in the penile shaft. The authors concluded that intracavernous injections were a useful alternative to implants but expressed concern over priapism and the unknown potential for adverse effects with long-term usage. Injections were not recommended for patients with sickle-cell disease, coagulation defects, or those experiencing adverse reactions to a test dose of drug.

Nellans et al reported on their experience with papaverine/phentolamine in 69 patients with organic or psychogenic impotence (129). Sixty-seven percent of patients achieved a response satisfactory for intercourse; 74 percent of these responders practiced self-injections at home, and 50 percent of this group reported improvement in their ability to achieve erections without continued injections. Althof et al described a study of 82 patients with impotence of varied etiologies involved in a self-injection program using papaverine/phentolamine (130). Ninety-six percent of this group achieved satisfactory erection. The dropout rate was 35 percent. Morbidity included bruising, 26 percent; pain at injection site, 5 percent; abnormal liver function tests, 7 percent; and nodule development in penile shaft, 21 percent. The authors concluded that this technique was reasonable, reliable, and relatively safe.

In a large clinical series involving 336 patients with mixed etiologies of impotence, Sidi and Chen reported excellent results using papaverine alone or in combination with phentolamine (131). Patients with neurologic or psychogenic impotence had a 97-100 percent success rate. Patients with vasculogenic impotence had an 82 percent success rate. Of the original group, 273 elected to continue with treatment at home, and tolerance to the drug (lack of efficacy) developed in 9 percent of these patients. Six percent of patients had adverse reactions, and prolonged erections were noted in 3 percent of patients. After 1 year, 63 percent of patients continued self-injections at a frequency ranging from twice a week to once a month.

Stief et al reported on more than 4,800 self-injections using papaverine/phentolamine in 186 patients over a 2-year period. Less than 1 percent had prolonged erections, and no patient developed infection or fibrosis (132). In two other studies using similar treatments in 203 patients with a followup of 6-12 months there were infrequent complications, and results were regarded as excellent in the treatment of both organic and psychologenic impotence (133,134).

Goldstein reported on his experience with several thousand injections in 100 patients, 83 of whom were followed for more than 6 months (135). Two patients developed curvature of the penile erection with a Peyronie's plaque, and two other patients developed penile fibromas. Only four patients experience prolonged erections (longer than 4 hours). Hu et al have also reported the development of penile curvature deformities and fibrosis of the tunica albuginea after long-term (6-12 months) self-injection using papaverine/phentolamine. There has been a case report of a fatal pulmonary embolism associated with papaverine-induced priapism and thromboses in the penile dorsal vein and corpora (136).

A recent review of the worldwide use of tens of thousands of injections of papaverine and phentolamine in over 4,000 patients documents its acceptance in both the diagnosis and treatment of impotence (118). Reported morbidity included hematomas, 5-10 percent; pain at injection site; 2 percent; and urethral damage, 2.5 percent. Rarely encountered morbidity included infections, penile fibrosis, hypotension, dizziness, and hepatotoxicity. Prolonged erections were noted in 5-15 percent of cases and were generally treated by local injections of the sympathomimetic drug metaraminol. Approximately 60 percent of patients continued self-injections after 1-2 years of use, attesting to patient acceptability.

Prolonged erections and the development of penile fibrosis appear to be the complications of the use of papaverine/phentolamine arousing the greatest concern. Fibrosis is generally reversible following discontinuation of the injections (137). However, the presence of fibrosis may compromise the success of future implant surgery (138).

Ideally, the goal of intracavernous injections is to produce a satisfactory erection lasting 30-45 minutes, with a maximum frequency of 1-2 injections per week to minimize morbidity (39). Prolonged erections (over 4-6 hours) predispose to irreversible smooth muscle necrosis, ischemic damage of the cavernosal tissues with irreversible scarring, and deterioration of the tightness of the tunica albuginea, all of which can result in further erectile dysfunction secondary to treatment (36,111,139). Prolonged erections are generally manageable by treatment with aspiration of blood from the corpora (5-70 mL) and/or irrigation of the tissues with diluted solution of phenylephrine, dopamine, epinephrine, or metaraminol (140,141). Surgical shunting procedures have occasionally been required but are rarely indicated (78,142).

There has been some preliminary experience with an implantable drug delivery system designed to overcome some of the morbidity associated with direct intracavernosal injections (143). Experience with the injection of drugs other than papaverine and phentolamine has been quite limited. Intestinal polypeptide has been demonstrated to be only partially effective (144). The use of PGE(1) appears to exhibit a mechanism of action similar to that of papaverine in inducing erections; however, it is metabolized much more rapidly, which may account for the lack of associated systemic reactions or prolonged erections (45,116). Reports of the efficacy of PGE(1) have been somewhat contradictory. Stackl et al report a 68 percent positive response to PGE(1) (143 of 210 patients) versus an 83 percent response to papaverine (116). Porst reported on 61 patients given PGE1. He found it to be twice as effective as a papaverine/phentolamine combination (145).

### Endocrine treatment

The precise contribution of androgen, luteinizing hormone, and prolactin to erectile physiology is not completely understood, making endocrine treatment somewhat empiric (118). In general, hormonal therapy represents a specific treatment for a known endocrine abnormality, and such treatment can restore potency to most patients with endocrine-associated dysfunction (13). Indications for the use of testosterone is limited to patients with proven hypogonadism, and testosterone replacement therapy has a significant dose-dependent effect on libido, coital frequency, total number of erections, and ejaculation (28,118). However, in some patients, only libido is improved with little or no effect on potency (146).

Elevated levels of prolactin are known to be associated with impotence. The prolactin-lowering effects to dopamine agonists such as bromocriptine and apomorphine as well as dihydroxyphenylalanine have achieved modest success in the treatment of impotence in trials involving limited numbers of patients (147,148). Apomorphine has been reported to induce erections in both potent and impotent men.

In a study of eight impotent subjects tested with apomorphine or placebo injected subcutaneously, four of the eight patients developed full erections within 5-15 minutes (149). Three of the four responders had elevated basal prolactin levels. It was suggested that apomorphine may be used to identify a subgroup of patients with impairment of central dopamine agonist function who might respond to treatment with bromocriptine. However, bromocriptine is of little value unless hyperprolactinemia is a component of the impotence (150). Bromocriptine has also been shown to be useful in restoring sexual function to patients whose impotence is related to long-term hemodialysis (151).

### Other therapeutic agents

A recent controlled clinical trial using oral phentolamine has demonstrated its effectiveness in producing tumescene and enhanced responses to sexual stimulation in 11 of 16 patients with nonspecific impotence (152). The use of nitroglycerine paste (as a smooth muscle relaxant) applied to the shaft of the penis has also been shown to produce satisfactory erections in various clinical trials (15,22,153). However, the limited data are insufficient for a proper evaluation of its safety and efficacy.

Yohimbine has had a long history as a reputed aphrodisiac, but this has not been well documented by clinical studies (118). Yohimbine is an indolalkylamine alkaloid derived from Rubacea and related trees. Its action is that of blocking presynaptic alpha-2 adrenergic receptors resulting in increased parasympathetic and decreased sympathetic activity (24). This alpha-adrenoceptor blocking effect is the same as that of the commonly used intracavernosal agents. Although the mechanism of action of yohimbine in treating impotence is unclear (including possible central nervous system effects), it has been speculated that its use might increase nonadrenergic activity at the alpha-1 adrenoceptor level in the penile sympathetic plexus, constrict shunt arterioles connecting the corpus cavernosa with the corpus spongiosum, and lead to an erection (18,99). However, it has been shown that alpha-1 adrenoceptor stimulation decreases penile blood flow, which appears to confound this hypothesis (154).

In an uncontrolled study of yohimbine in 23 patients with organic impotence of varied etiologies, an oral dose of 6 mg, three times a day, for a minimum of 10 weeks, produced full erections and resumption of satisfactory sexual performance in six patients (26) (99). Thirteen patients (56) reported no improved erectile function. Four patients (17) reported improved but unsatisfactory erections. The drug was well tolerated. Side effects included nausea, dizziness, and nervousness noted among three patients. A recent placebo-controlled, double-blind, 10-week trial of yohimbine in 48 patients with psychogenic impotence demonstrated improved sexual function in 62 percent of patients versus only 16 percent with the placebo (155). The effect in responders was noted in 2-3 weeks; however, there was no method of determining which patients were likely to respond to the drug.

In another randomized controlled trial by Morales et al, this time using yohimbine in 100 patients with organic impotence, the response rate was thought to be, at best, marginal (156). The responses were 42.6 percent for yohimbine versus 27.6 percent for the placebo (p <0.5). There were no serious side effects of the drug. It has been reported that yohimbine combined with isoxsuprine (a beta-adrenergic stimulant) is sometimes effective in patients refractory to either agent alone (47).

### External devices

On the basis of observations that an erection-like state (tumescene) sufficient for intercourse can be achieved when a flaccid penis is placed in a vacuum, and that this state can be maintained by impeding venous outflow using a constriction band around the base of the penis, vacuum devices have been used in patients with organic or psychogenic impotence for the past 70 years (12,61,157). Currently, there are five such devices being marketed that are regarded as noninvasive, safe, effective, and relatively inexpensive methods for achieving sexual potency, especially for patients who are poor surgical candidates or object to other therapies (12,158). As a prerequisite for the use of these devices, patients must have manual dexterity and an adequate penile blood supply.

Vacuum/constriction devices represent a reversible therapeutic modality that can theoretically be used by almost any patient needing erectile enhancement (159). These devices are most effective in patients with partial impotence and are contraindicated for patients having blood dyscrasias or those taking anticoagulants. The device may also be used as a trial to determine if a satisfactory erection can be achieved prior to consideration of more invasive therapies.

The external vacuum devices are basically similar and consist of a hollow plastic cylinder, vacuum pump, connector tubing, and elastic constriction bands (12,159). Their use involves the application of a water-soluble lubricant to the entire flaccid penis and placing the cylinder over the penis to create an airtight seal. Plastic tubing fitted to the cylinder is attached to a vacuum pump that is activated to draw blood into the penis to produce an erection or augment an ineffective erection. When adequate tumescence is achieved, usually within 2-7 minutes, a constriction band is pushed down from the base of the cylinder around the base of the penis to trap blood within it. The vacuum is then released and the cylinder is removed. Tumescence is achieved only distal to the constriction band; therefore, the proximal portion of the penis remains flaccid (159). The erection is maintained for a sufficient time to permit intercourse. Normal orgasm, but no emission, may be achieved while the constriction band is in place (61). The recommended maximum use of the constriction band is 30 minutes since it produces both partial venous and arterial obstruction, distension of the superficial veins, and cyanosis of the penis. Petechiae and ecchymosis commonly occur with the use of these devices but are not clinically significant. Mild penile pain and/or numbness has been reported by some patients; however, in a small trial (nine-person) reported by Cooper, all participants expressed enthusiasm for continued use of the device (61).

Korenman et al tested a vacuum/constriction device in eight patients aged 49-69 with organic impotence of varied etiologies (160). Twenty-eight percent of patients had a history of no erections, and 72 percent reported inadequate erections. Three patients had failed to respond to intracavernosal papaverine injections. Eighty-four percent of these patients achieved satisfactory success using this device. Erections lasted a mean of 16 minutes and the device was preferred over intracavernosal injections or the consideration of an implant. These investigators concluded that this device was safe and Nadig et al used a vacuum device in 35 patients with organic impotence who had refused the option of a penile implant (157). Thirty-two of the group achieved penile rigidity sufficient for intercourse, and 24 patients continued regular use of the device with satisfactory results. Three failures in the initial group were associated with either a penile deformity due to prior surgery (one case) or problems associated with proper fit of the cylinder (two cases). Eight patients experienced numerous petechiae, three demonstrated ecchymosis, and two had painless swelling of the penis. All of these side effects were reversible.

An evaluation of vacuum devices by the Testing and Evaluation Program of the Veterans Administration (VA) Marketing Center found that in patients randomly recruited by referrals to VA urology services with either organic or psychogenic impotence who were using the devices, most were either satisfied with or enthusiastic about their performance in permitting sexual intercourse (161). These devices have now achieved widespread use throughout the VA hospital system, and during the year ending December 1988 more than 1,000 devices were distributed.

Another device that is not used extensively by the VA system but is nonetheless quite popular is the external splint. The splint is a semirigid, silicone rubber, condom-shaped apparatus that can be fitted over the penis (159). A small tube connected to the device permits air to be evacuated from its interior. A thin collar at the proximal open end of the device acts as a valve to form a seal around the penis following the evacuation of air. After lubricating both the device and the penis with water soluble jelly, the penis is placed into the device and a vacuum is created by mouth suction on the attached tubing that draws the flaccid penis into the device while simultaneously producing tumescence. The proximal collar is then unfolded toward the base of the penis to reduce the possibility of vacuum loss. The tubing is occluded by a valve and loosely wrapped around ridges on the base of the device. A lubricant is then applied to the exterior of the device to facilitate intercourse while the device is worn. Tumescence is retained as long as the device is Release of the vacuum lock-valve permits removal of the device. The primary adverse reaction reported was penile and vaginal irritation.

## Discussion

The fact that the majority of impotent patients have a multifactorial etiology has complicated the diagnosis and treatment of this common disorder. Individual indices of erectile dysfunction are rarely able to establish an etiologic diagnosis (162). Until a decade ago, NPT monitoring was the only objective method employed for the differential diagnosis of organic and psychogenic impotence and was regarded as a great improvement over the need to rely on subjective data (43,53). At the same time, excepting the relatively few specific therapies associated with specific diagnoses (for example, endocrine disorders, Leriche syndrome), the most frequent nonspecific therapy for organic impotence was the use of an implantable prosthesis, which does not restore libido, ability to ejaculate, or penile sensation (47).

Currently, there is a wide range of diagnostic and therapeutic modalities applied to the management of impotence. Until the advent of intracavernosal injections of vasoactive drugs, NPT was the only unequivocal direct test of physiological erectile capacity and was regarded as mandatory in the evaluation of impotence (45,163). NPT testing is still considered by some investigators as the best noninvasive method to differentiate organic from psychogenic impotence (38). However, by any method, NPT has a high incidence of false-negative and false-positive results, has not been validated as a reliable technique, and is now regarded by many investigators as having little value in the diagnostic workup for impotence despite its frequent use as a screening device (especially after vascular disease has been excluded as an etiology) (5,12,37,55). The evaluation of penile arterial flow and blood pressure by ultrasound and the intracavernosal injection of papaverine are now the most common, direct, and simple techniques used to evaluate vasculogenic impotence (12,21,45,120). A penile brachial index (by Doppler) of less than 0.6-0.75 is highly suggestive of vasculogenic impotence (20,69). Despite the fact that intracavernosal injections of vasoactive drugs has had widespread clinical use since 1982 and can obviate extensive, time consuming testing for the differential diagnosis of vasculogenic from other etiologies of impotence, controversy continues concerning its reliability for this purpose (18,45,84,164,165). A clearly normal response to intracavernosal papavarine injection can exclude venous shunting or extrapenile arterial insufficiencies as an etiology for impotence, and an abnormal response to a papaverine injection combined with a normal PBI indicates venous leakage as the source of the problem (12,164). Many investigators advocate the use of Doppler ultrasound before and after intracavernosal injections of papaverine for the diagnosis of vasculogenic impotence (66,73,76). The intracavernosal injection of papaverine may be useful in suggesting venous leakage; however, it cannot differentiate the various forms of venous incompetence. A definitive diagnosis of erectile dysfunction related to venous abnormalities includes an accurate determination of cavernosal flow rates and pressures, which requires cavernosography and cavernosometry (87).

Although there is excellent correlation between Doppler ultrasound and angiography in the diagnosis of vasculogenic impotence, angiography can demonstrate disease in some patients with a normal examination by Doppler (21). However, its morbidity and the need for anesthesia makes penile angiography difficult to justify in the climate of variable long-term success of reconstructive surgery (12,25,57,106,146). Still, angiography continues to be recommended as a prerequisite in candidates for revascularization (11,45,101,146). Other invasive and noninvasive tests to determine penile vascular competence have not been adequately validated in clinical trials, and their general application is not warranted.

Abnormal evoked-potentials and biothesiometry are highly correlated with neurological disease and appear to have been generally accepted as reasonable techniques for the neurological assessment of impotent patients (17,93). The determination of testosterone and prolactin levels is the minimal laboratory requirement to exclude an endocrinologic basis for impotence (11,137,166). A full evaluation of the hypothalamic-pituitary-gonadal axis is undertaken when other suggestive abnormalities are detected.

Excepting surgical implants, intracavernosal injections, and specific endocrine therapy, there has been a paucity of clinical trials and little evidence of benefit from any medical therapy in the treatment of impotence (15,37). The use of systematic drugs has achieved good results in a small percentage of patients with impotence (133). However, it has been difficult to identify which patient may benefit (133). Vascular surgery as a treatment for impotence has had only limited success in correcting arterial or venous abnormalities of the penis (11,25,100,114,133,167). However, relatively good results have been achieved in treating aortoarterial occlusive disease (103). Despite reports of good results in selected patients, many investigators continue to regard penile arterial and/or venous surgery as either investigational or requiring further evaluation (11,21,100,112,160).

The use of intracavernosal injections of vasoactive drugs that bypass psychological, neurologic, and hormonal influences on impotence offers an apparently popular treatment alternative to penile implant or revascularization surgery (119,120,128). However, concerns over priapism, medicolegal responsibilities, and long-term morbidity persist (64,78,131,163). In addition, the ideal drug, dosage, and schedule of administration have not been determined, and the application of these vasoactive agents represents the use of FDA-approved drugs for a nonlabeled indication (11,78,120). Despite the enormous popularity and demonstrated effectiveness of intracavernosal injections, some investigators recommend more followup before routine clinical application and consider its use to be investigational (21,84,119).

A long record of clinical experience suggests that most impotent patients can achieve intercourse with the use of an external vacuum device, with no significant complications. Penile prosthetic implants continue to remain an option for those patients failing simpler alternatives including oral medication, intracavernosal injections, external vacuum devices, or revascularization (19).

In response to the Federal Register notice of this assessment (168). and the solicitation of information and opinions from Federal agencies, the Office of Health Technology Assessment has received a number of letters:

- The University of Minnesota, Department of Urologic Surgery stated that the use of intracavernosal vasoactive drugs is an accepted medical practice for the diagnosis of impotence. However, the high percentage of false-positive and false-negative results makes its value in differential diagnosis unproven.

With regard to the use of intracavernousal drugs for the treatment of impotence, they state that no universal guidelines exist, and they have some concern regarding the unknown effects of long-term use. It is their opinion that the home use of NPT testing is safe and useful. They report apparent good results from revascularization surgery for impotence after pelvic trauma, with 30 percent long-term success for small vessel disease, and report no long-term data on venous surgery (169).

- The Baylor University Sleep Disorder and Research Center believes that NPT testing devices are safe but false-positive results are common, and the validity of self-testing is questionable. They are of the opinion that intracavernosal injections for diagnostic purposes are relatively safe but not an accepted diagnostic technique for impotence. They point out that intracavernosal injections have not been studied in a prospective trial. They state that intracavernosal injections are not safe for home use, and that most emergency rooms are poorly equipped to deal with priapism. They believe that vein ligation surgery may be a successful treatment for selected causes of impotence; however, long-term results of revascularization surgery are questionable (170).
- The National Institutes of Health has informed OHTA that the degree and nature of organic impotence has been evaluated by penile vascular Assessment methods, neurological testing, blood tests, and NPT testing. However, there are no universally accepted methods for evaluation of these tests.

Although NPT has been used to differentiate between organic and psychogenic impotence, both false-positive and false-negative results occur with appreciable Its use should be restricted to controlled laboratory conditions; home use of NPT testing has very little credibility and serves little purpose.

Plethysmography allows NPT-associated measurement of pulse volume and pressure, typically with a comparison of penile and brachial pressures, in the diagnosis of vasculogenic impotence; however, it is not specific for the blood supply to the corpus cavernosum.

Penile blood pressure is regarded as more useful than NPT testing. The PBI is widely used and has great specificity but poor sensitivity for evaluating the vascular contribution to impotence. However, normal response values are not well established.

Doppler ultrasound scanning is a widely used, safe, and effective technique to detect arterial insufficiency. Doppler ultrasound is simpler and less expensive than plethysmography as a screening method for vasculogenic impotence. It is increasingly being used alone or together with papaverine injection as an accepted diagnostic technique. An abnormal Doppler finding is highly predictive of vascular disease as a cause of impotence.

Diagnostic injection of smooth muscle relaxing drugs will cause erection in the normal individual. Intracavernosal injections of papaverine are commonly used to confirm the existence of vascular impotence and assess the probability of venous leakage, but there is insufficient evidence to evaluate drugs other than papaverine and phentolamine as diagnostic agents. The use of these agents is associated with a definite but small risk of temporary priapism. Diagnostic injections are now accepted medical practice. Increasingly, papaverine or papaverine/phentolamine is used together with preand postinjection ultrasound scanning to evaluate the functional status of the arteries. In addition, combining the injection with visual sexual stimulation creates a more normal context than injections alone. Diagnostic injections should be done only under controlled conditions, both for the sake of validity and to check for drug reactions.

The widespread use of these agents in treatment has demonstrated short-term safety and efficacy. However, long-term safety may be a problem, and limited data concerning this issue are available. The home use of intracavernosal injection is suitable for selected patients.

Cavernosography/cavernosometry carries increased risk of complications, albeit small, and is used when necessary to diagnose venous leakage.

The penile injection of papaverine/phentolamine has proved its usefulness in the treatment of impotence. The procedure can cause temporary priapism in an appreciable number of patients, but this is seen much less often in centers with extensive expertise and experience. Aside from this complication, these drugs are safe and effective in short-term use. Although the longer term data available suggest a low rate of complications, some believe there is evidence of a higher long-term risk of permanent penile damage due to fibrosis.

A preliminary controlled evaluation of oral phentolamine, if confirmed in more extensive testing, may provide a therapeutic alternative to injections with greater promise for long-term safety and effectiveness. Meanwhile, there is evidence that oral yohimbine may be safe and effective. If confirmed, this drug could be used as an alternative to penile injections.

The use of external vacuum devices to induce erections has become an accepted practice. Revascularization surgery, for those vascular pathologies amenable to it, and in experienced hands, is a safe and effective alternative for the treatment of impotence that approaches the success rates of many of the nonsurgical methods. Unfortunately, reported results in the United States to date are based on small numbers of patients, and there are no controlled clinical trials available on which to base a more definitive assessment.

- The Food and Drug Administration has informed OHTA that the validity and reliability of the home use of NPT testing has not been established. Penile duplex ultrasonography appears to be a research tool. The long-term safety of papaverine injections is not established, and the safety and effectiveness of the various drugs used as intracavernosal injections has not been established by Investigational New Drug (IND) or New Drug Application (NDA) procedures. There are five vacuum devices that are regarded as safe and effective that are currently allowed to be marketed for the enhancement of intercourse in patients with some functional ability.

## Summary

A multifactorial etiology exists in most cases impotence, with organic factors playing a major, and psychologic factors only a minor, role. The evaluation and treatment of this common disorder requires a multidisciplinary approach. Although there are no validated, objective measures of erectile function that correlate with sexual ability, commonly used invasive and noninvasive evaluation procedures have evolved from clinical experience and include physical and psychological examinations, hormonal assays, penile circulation testing, nocturnal penile tumescence testing, and electrophysiological evaluations. Excluding implantable penile prostheses and psychotherapy, treatment options from impotence include oral drugs, intracavernosal injections of vasoactive agents, external devices, or vascular surgery.

Although controversial and frequently employed, NPT testing is regarded by many investigators as having little diagnostic value in home or laboratory settings. Currently, intracavernosal papaverine injections and ultrasound evaluation of penile erection are the most commonly used techniques to evaluate vasculogenic impotence. The diagnostic use of intracavernosal smooth muscle relaxing drugs is regarded as safe and effective and represents a widely accepted medical practice. Angiography is generally reserved for potential candidates for revascularization. Other tests for penile vascular competence have not been clinically validated. Evoked-potential testing and biothesiometry are accepted techniques for the neurological assessment of impotence.

Excepting surgical implants, intracavernosal injections, and specific endocrine therapy, there is little evidence of benefit from other treatments for impotence. Vascular surgery, other than for aortoarterial disease, has had only limited success and is generally regarded as investigation or requiring further followup. The use of intracavernosal injections has achieved enormous popularity as an alternative to surgery; however, concerns over priapism and long-term morbidity persist. Despite these concerns, these injections have been regarded as accepted medical practice in both the clinic and for self-administration at home. At present, the intracavernosal injection of vasoactive agents for either diagnosis or treatment represents the use of FDA-approved drugs for unlabeled indications. External vacuum devices designed to permit impotent patients to achieve intercourse have become increasingly popular and are regarded as safe and effective.

## References

1 Morley JE. Impotence Am J Med 1986 80: 897 905View this and related citations using 3518438
2 Michie DD. Causes of impotence in elderly men and considerations for treatment of impotence Geriatric Med Today 1988 7: 38 44
3 [no authors listed] Impotence Study Group of Western Australia. The diagnosis and treatment of impotence Med J Austral 1988 148: 494 498
4 Morales A, Marshall PG, Surridge DH. Corporeal calibration: A discriminatory test for impotence J Urol 1982 128: 41 43 7109068
5 Wincze JP, Bansal S, Malhotra C, et al. A comparison of nocturnal penile tumescence and penile response to erotic stimulation during waking states in comprehensively diagnosed groups of males experiencing erectile Arch Sex Behav 1988 17: 333 348 3421827
6 Korenman SG. Epidemiology and impact of sexual dysfunction in: Abstracts; Conference on the Scientific Basis of Sexual Dysfunction National Institutes of Health, Baltimore, MD, June 4-6, 1986.
7 Bohlen JG. Sleep erection monitoring in the evaluation of male erectile failure Urol Clin N Amer 1981 8: 119 134
8 MarseyMassey FJ, Bernstein GS, O'Fallon WM, et al. Vasectomy and health: Results from a large cohort study JAMA 1984 252: 1023 1029 6748206
9 Whitehead ED. Diabetes-related impotence: Putting new knowledge to waste Geriatrics 1989; 1988 43: 114 120
10 Martin CE. Sexual activity in the aging male in Money J, Musoph H (Eds): Handbook of Sexology, New York: Elsevier, 1977 pp. 513 524
11 Williams G. Erectile dysfunction: Diagnosis and treatment Br J Urol 1987 60: 1 5 3304512
12 Johnson LE, Morley JE. Impotence in the elderly Am Fam Phys 1988 38: 225 240
13 Spark RF, White RA, Connolly RB. Impotence is not always psychogenic. Newer insights into hypothalamic-pituitary-gonadal dysfunction JAMA 1980; 243: 750 755 7351816
14 Cooper AJ. Advances in the diagnosis and management of endocrine impotence Practitioner 1984 228: 865 870 6473298
15 Morales A, Condra MS, Owen JE, et al. Oral and transcutaneous pharmacologic agents in the treatment of impotence Urol Clin N Amer 1988 15: 87 101
16 Wasserman MD, Pollak CP, Spielman AJ, et al. Theoretical and technical problems in the measurement of nocturnal penile tumescence for the differential diagnosis of impotence Psychosom Med 1986; 1980 42: 575 585
17 Padma-Nathan H, Goldstein I, Krane RJ. Evaluation of the impotent patient Semin Urol 1986; 4: 225 232 3797891
18 Orvis BR, Lue TF. New therapy for impotence Urol Clin N Amer 1987; 14: 569 581
19 Nelson RP. Nonoperative management of impotence J Urol 1988; 39:
20 Baum N. Treatment of impotence 2. Surgical methods Postgrad Med 1987; 81: 137 140
21 Morley JE. Impotence Am J Med 1986 80: 897 905 3518438
22 Rivard DJ. Anatomy, physiology and neurophysiology of male sexual function in AH Bennett (Ed): Management of Male Impotence, Baltimore: Williams and Wilkins, 1982, pp. 1 25
23 Collins WE, McKendry JBR, Silverman M, et al. Multi-disciplinaryMultidisciplinary survey of erectile impotence Can Med Assoc J 1985;1983 128: 1393 1399 6850465
24 Kosch SG, Curry RW Jr, Kuritzky L. Evaluation and treatment of impotence. A pragmatic approach addressing organic and psychogenic components Fam Prac Rest J 1988 3: 162 174
25 Nath RL, Menzoian JO, Kaplan KH, et al. The multidisciplinary approach to vasculogenic impotence Surg 1981 89: 124 133
26 Kaiser F, Viosca SP, Morley J, et al. Impotence and aging: Clinical and hormonal factors J Am Geriatric Soc 1988 36: 511 519
27 Montague DK, James RE, de Wolfe VG, et al. Diagnostic evaluation, classification, and treatment of men with sexual dysfunction Urol 1979 14: 545 548
28 McClure RD. Endocrine evaluation and therapy of erectile dysfunction Urol Clin N Amer 1988 15: 53 64
29 Maatman TJ, Montague DK. Routine endocrine screening in impotence Urol 1986 27: 499 502 3716048
30 Morley JE, Melmed S. Gonadal dysfunction in systemic disorders Metabolism 1979; 28: 105 173 33319
31 De Palma RG, Emeellem Emsellem HA, Edwards CM, et al. A screening sequence for vasculogenic impotence J Vasc Surg 1987 5: 228 236 3820400
32 Padma-Nathan H. Neurologic evaluation of erectile dysfunction Urol Clin N Amer 1988 15: 77 80
33 Blum MD, Bahnson RR, Porter TN, et al. Effects of local alpha-adrenergic blockade on human penile erection J Urol 1985 134: 179 181
34 Aboseif SR, Lue TF. Hemodynamics of penile erection Urol Clin N Amer 1988 15: 1 7
35 Silber SJ. Impotence Adv Intern Med 1984 30: 359 385 6397041
36 Mandel E. Diabetes-related impotence and self-injection therapy Practical Diabetol 1988; 230: 9230 926
37 Williams G, Kiely EA. The management of erectile impotence Practitioner 1986 230: 923 926 3658901
38 Kessler WO. Nocturnal penile tumescence Urol Clin N Amer 1988; 15:
39 Sidi AA. Vasoactive intracavernous pharmacotherapy Urol Clin N Amer 1988 15: 95 101
40 Condra M, Morales A, Surridge D, et al. Evaluation of the urological assessment in impotence: Findings with a new diagnostic rating scale J Urol 1984 131: 486 490
41 Bradley WE, Timm GW, Gallagher JM, et al. New method for continuous measurement of noctural nocturnal penile tumescense and rigidity Urol 1985; 26: 4 9
42 Earls CM, Morales A, Marshall WL. Penile sufficiency: An operational definition J Urol 1988 139: 536 538 3343740
43 Wabrek AJ. Nocturnal penile tumescence (NPT) monitoring: Its role in the differential diagnosis of impotence Conn Med, October 1979
44 Karacan I, Ilaria RL. Nocturnal penile tumescence (NPT): The phenomenon and its role in the diagnosis of impotence Sexual Disabil 1978 1: 260 271
45 Mueller SC, Lue TF. Evaluation of vasculogenic impotence Urol Clin N Amer 1988 15: 650 76
46 Kaneko S, Bradley WE. Evaluation of erectile dysfunction with continuous monitoring of penile rigidity J Urol 1986 136: 1026 1029 3773061
47 Nelson RP. Male sexual dysfunction: Evaluation and treatment S Med J 1987 80: 69 74
48 Thase ME, Reynolds CF III, Jennings JR, et al. Nocturnal penile tumescence is diminished in depressed men Biol Psychiatry 1988 24: 33 46 3370276
49 Owen J, Condra M, Phillips P, et al. Transcutaneous nitroglycerine enhances the quality of erections in impotent men. Results of a controlled trial J Urol 1987 137:
50 Fisher C, Schiavi RC, Edwards A, et al. Evaluation of nocturnal penile tumescence in the differential diagnoses of sexual impotence Arch Gen Psychiatry 1979 36: 431 437 426610
51 Schiavi RC. The role of NPT: Somatic versus psychological in: Abstracts; Conference on the Scientific Basis of Sexual Dysfunction National Institutes of Health,, Baltimore, MD June 4-6, 1986
52 Marshall P, Morales A, Surridge DH. Diagnostic significance of penile erections during sleep Urol 1982 20: 1 6
53 Karacan I, Scott FB, Salis RJ, et al. Nocturnal erections, differential diagnosis of impotence, and diabetes Biol Psych 1977 12: 373 382
54 Earls CM, Morales A, Marshall WL. Penile sufficiency: An operational definition J Urol 1988 139: 536 538 3343740
55 Marshall PG, Morales A, Phillips P, et al. Nocturnal penile tumescence with stamps: A comparative study under sleep laboratory conditions J Urol 1983 130: 88 89
56 Marshall PG, Earls C, Morales A, et al. Nocturnal penile tumescence recording with stamps: A validity study J Urol 1982 128: 946 947
57 Condra M, Morales A, Fenemore J, et al. Screening assessment of penile tumescence and rigidity. Clinical test of Snap-Gauge Urol 1987 29: 254 257 3824719
58 Barry JM, Black Blank B, Boileau MA. Nocturnal penile tumescence monitoring with stamps Urol 1980 15: 171 172 7355543
59 Bertini J, Boileau MA. Evaluation of nocturnal penile tumescence with Poten Test Urol 1986 27: 492 494
60 Ek A, Bradley WE, Krane RJ. Nocturnal penile rigidity measured by the Snap-Gauge band J Urol 1983 129: 964 966
61 Cooper AJ. Preliminary experience with a vacuum constriction device (VCD) as a treatment of impotence J Psychosom Res 1987 31: 413 418 3625595
62 Bradley WE. New techniques in evaluation of impotence Urol 1987 129: 383 388 3564211
63 Morales A, Marshall PG, Surridge DH. A new device for diagnostic screening of penile tumescence J Urol 1983 129: 288 290 6834491
64 Condra M, Morales A, Surridge DH, et al. The unreliability of nocturnal penile tumescence recording as an outcome measurement in the treatment of organic impotence J Urol 1986 135: 280 282 3944859
65 Gaskell P. The importance of penile blood pressure in cases of impotence Can Med Assn J 1971 105: 1047 1051
66 Elliott BM, Collins GJ, Youkey JR, et al. The noninvasive diagnosis of vasculogenic impotence J Vasc Surg 1986 3: 493 497
67 Wheeler D, Rubin HB. A comparison of volumetric and circumferential measures of penile erection Arch Sex Behav 1987 4: 289 299 3675182
68 Doyle DL, Yu J. Comparison of Doppler and strain-gauge plethysmography to detect vasculogenic impotence Can J Surg 1986 29: 338 339 3530411
69 Velcek D, Sniderman KW, Vaugh ED Jr, et al. Penile flow index utilizing a Doppler pulse wave analysis to identify penile vascular insufficiency J Urol 1980 123: 669 673 7420553
70 Kedia KR. Penile plethysmography useful in diagnosis of vasculogenic impotence Urol 1983 22: 235 239 6623767
71 DuPlessis DJ, Boormann Bornman MS, Koch Z, et al. Penile ultrasonography in impotence S Afr J Surg 1987 25: 69 71 3299755
72 Goldstein I, Siroky MB, Nath RL, et al. Vasculogenic impotence: Role of the pelvic steal test J Urol 1982 128: 300 306 7109096
73 Chiu RC, Sidstone Lidstone D, Blundell PE. Predictive power of penile/brachial index in diagnosing make sexual impotence J Vasc Surg 1986 4: 251 256 3528532
74 Bell D, Lewis R, Kerstein MD. Hyperemic stress test in diagnosis of vasculogenic impotence Urol 1983 22: 611 613
75 Jevtich MJ. Penile body temperature as a screening test for penile arterial obstruction in impotence Urol 1981 17: 132 135 7467013
76 Lue TF. Pharmacologic tools in evaluation in: Abstracts; Conference on the Scientific Basis of Sexual Dysfunction National Institutes of Health,, Baltimore, MD, June 4-6, 1986
77 Lue TF, Kricak Hricak H, Schmidt RA, et al. Functional evaluation of penile veins by cavernosography in papaverine-induced erection J Urol 1986 135: 479 482
78 [no authors listed] Intracavernous injection for impotence Med Letter 1987 29: 95 96
79 Mellinger BC, Vaughan ED Jr., Thompson SL, et al. Correlation between intracavernous papaverine injection and Doppler analysis in impotent men Urol 1987 30: 416 419 2960063
80 Juenemann Junemann KP. Open multi-centermulticenter study of the differential diagnosis of erectile dysfunction with a papaverine-phentolamine combination Urologe 1988 27: 2 7
81 Brindley GS. Cavernosal alpha blockage alpha-blockade: A new technique for investigating and treating erectile impotence Br J Psychiat 1983 143: 332 337
82 Robinette MA, Moffat MJ. Intracorporeal Intracorporal injection of papaverine and phentolamine in the management of impotence Br J Urol 1986 58: 692 695 3801830
83 Strachan JR, Pryor JP. Diagnostic intracorporeal papaverine and erectile dysfunction Br J Urol 1987 59: 264 266
84 Abber JC, Lue TF, Orvis BR, et al. Diagnostic tests for impotence: A comparison of papaverine injection with the penile-brachial index and nocturnal penile tumescence monitoring J Urol 1986 135: 923 925 3959242
85 Buvat J, Lemaire A, Dehaene JL. Venous incompetence: Critical study of the organic basis of high maintenance flow rates during artificial erection test J Urol 1986; 135: 926 928 3959243
86 Malhotra CM, Balko A, Wincze JP, et al. Cavernosography in conjunction with artificial erection for evaluation of venous leakage in impotent men Radiology 1986 161: 799 802 3786736
87 Porst H, van Ahlen H, Vahlensiek W. Relevance of dynamic cavernosography to the diagnosis of venous incompetence in erectile dysfunction J Urol 1987 137: 1163 1167 3586148
88 Porst H, Altwein JE, Bach E, et al. Dynamic cavernosography. Venous outflow studies of cavernous bodies J Urol 1985 134: 276 279
89 Nseyo UO, Wilbur HJ, Kang SA, et al. Penile Xenon (133 Xe) washout: A rapid method of screening for vasculogenic impotence Urol 1984 23:
90 Hauri D, Spycher M, Bruhlmann W. Erection and priapism: A new physiopathological concept Urol Int 1983 38: 138 145 6868212
91 Siroky MB, Sax DS, Krane RJ. Sacral signal tracing: The electrophysiology of the bulbocavernous bulbocavernosus reflex J Urol 1979 122: 661 664 159365
92 Wabrek AJ. Bulbocavernous Bulbocavernosus reflex testing in 100 consecutive cases of erectile dysfunction Urol 1985 25: 495 498
93 Padma-Nathan H, Levine F. Vibratory testing of the penis J Urol 1987 137:
94 Ertekin C, Ertekin N, Mutlus S, et al Skin potentials (SP) recorded from the extremities and genital regions in normal and impotent subjects Acta Neurol Scan 1987 76: 28 36
95 Montague K. The evaluation of the impotent male in Bennett AH (Ed): Management of Male Impotence, Baltimore: Williams and Wilkins, 1982 pp. 52 61
96 Mudd JW. Impotence responsive to glyceryl trinitrate Am J Psych 1977 134: 922 925
97 Bommer J, Ritz E, del Pozo E, et al. Improved sexual function in male hemodialysis haemodialysis patients on bromocriptine Lancet 1979 2: 496 497
98 Antgoinous Antoniou LD, Shalhoub RJ, Sudhakar T, et al. Reversal of uremicuraemic impotence by zinc Lancet 1977 2: 895 898 72240
99 Morales A, Surridge DHC, Marshall PG, et al. Nonhormonal pharmacological treatment of organic impotence J Urol 1982 128: 45 47 6125605
100 Shaw WW, Zorgniotti AW. Surgical techniques in penile revascularization Urol 1984; 23: 76 82 6719685
101 Bennet Bennett AH, Rivard DJ, Blanc RP, et al. Reconstructive surgery for vasculogenic impotence J Urol 1986 136: 599 601 3735536
102 Queral LA, Whitehouse WM, Flinn WR, et al. Pelvic hemodynamics after aortoiliac reconstruction Surg 1979 86: 799 809
103 Crespo E, Soltanik E, Bove D, et al. Treatment of vasculogenic sexual impotence by revascularizing cavernous and/or dorsal arteries using microvascular techniques Urol 1982 20: 271 275 7123719
104 Virag R. Revascularization of the penis in Bennett AH (Ed): Management of Male Impotence Baltimore: Williams and Wilkins, 1982 pp. 219 233
105 Virag R, Spencer PP, Frydman D. Artificial erection on diagnosis and treatment of impotence Urol 1984 24: 157 161
106 Bennett AH. Venous arterialization for erectile impotence Urol 1984 24: 157 161
107 Balko A, Malhotra CM, Wincze JP, et al. Deep-penile-vein arterialization for arterial and venous impotence Arch Surg 1986 121: 774 777 3718211
108 Goldstein I. Arterial revascularization procedures Semin Urol 1986 4: 252 258 3797897
109 Pearl RM, McGhee RD. Penile vascularization in the treatment of vasculogenic impotence Plast Reconstr Surg 1987 80: 284 289
110 McDougal WS, Jeffrey Jeffery RF. Microscopic penile revascularization J Urol 1983 129: 517 521 6834535
111 Tudoriu T, Bourmer H. The hemodynamics of erection at the level of the penis and its local deterioration J Urol 1983 129: 741 745 6842691
112 Puyau FA, Lewis RW, Balkin P, et al. Dynamic corpus cavernosography: Effect of papaverine injection Radiol 1987 164: 179 182
113 Wespes E, Schulman CC. Venous leakage: Surgical treatment of a curable cause of impotence J Urol 1985 133: 796 798 3989919
114 Lewis RW. Venous surgery for impotence Urol Clin N Amer 1988; 15: 115 121
115 Courtheroux Courtheoux P, Maiza D, Henriet JP, et al. Erectile dysfunction caused by venous leakage: Treatment with detachable balloons and coils Radiol 1986 161: 807 809
116 Stackl W, Hasun R, Marberger M. Intravenous injectionsIntracavernous injection of prostaglandin E1 in impotent men J Urol 1988 140: 66 88
117 Virag R. Intracavernous injection of papaverine for erectile failure Lancet 1982 2:
118 Malloy TR, Malkowicz B. Pharmacologic treatment of impotence Urol Clin N Amer 1987 14: 297 304
119 Zentgraf M, Baccouche M, Junemann KP. Diagnosis and therapy of erectile dysfunction using papaverine and phentolamine Urol Int 1988 43: 65 75 3291360
120 Zorgniotti AW, Lefleur RS. Auto-injection of the corpus cavernosum with a vasoactive drug combination for vasculogenic impotence J Urol 1985 133: 39 41 2578067
121 Goldstein I, Payton TR, Saenz de Tejada D, et al. Pharmacologic erections: Role in the treatment of neurogenic impotence (abs) J Urol 1985 133:
122 Kiely EA, Williams G, Goldie L. Assessment of the immediate and long-term effects of pharmacologically induced penile erection in the treatment of psychogenic and organic impotence Br J Urol 1987; 59: 464 469 3427321
123 Kiely EA, Ignotus P, Williams G. Penile function following intracavernosal injection of vasoactive agents or saline Br J Urol 1987 59: 437 476
124 Hauri D. Arterially originated erectile disturbances: Surgical possibilities and their alternatives -Some personal thoughts Urol Int 1988 43: 76 84 3291361
125 Hauri D, Spycher M, Bruhlmann W. Erection and priapism: A new physiopathological concept Urol Int 1983 38: 138 145 6868212
126 Sharafi ML, Sharafi R. Information and treatment with intracavernous injections of papaverine and phentolamine J Urol 1986 136: 1008 1010 (Letter) 3959225
127 Sidi AA, Cameron JS, Dykstra DD, et al. Vasoactive intracavernous pharmacotherapy for the treatment of erectile impotence in men with spinal cord injury J Urol 1987 138: 539 542
128 Lue TF, Tanagho EA. Physiology of erection and pharmacological management of impotence J Urol 1987 137: 829 836 3553617
129 Nellans RE, Ellis LR, Kramer-Levine D. PharmacologicPharmacological erection: Diagnosis and treatment applications in 69 patients J Urol 1987 1388: 52 54 2439712
130 Althof SE, Turner LA, Levine SB, et al. Intracavernosal injection in the treatment of impotence: A perspective prospective study of sexual, psychological, and marital functioning J Sex Marital Ther 1987 13: 155 167 2444712
131 Sidi AA, Chen KK. Clinical experience with vasoactive intracavernous pharmacotherapy for treatment of impotence World J Urol 1987 5: 156 159 8401634
132 Stief CG, Thon WF, Scherb W, et al. (1987). Two years' experiences with cavernosal autoinjection therapy. Urologe.
133 Robinette MA, Moffat MJ. Intracorporeal Intracorporal injection of papaverine and phentolamine in the management of impotence Br J Urol 1986 58: 692 695 3801830
134 Hu K, Burks C, Christy WC. Fibrosis of tunica albuginea: Complication of long-term intracavernous pharmacological self-injection J Urol 1987 138: 404 405
135 Goldstein I. Intracorporal pharmacologic therapy in: Abstracts; Conference on the Scientific Basis of Sexual Dysfunction National Institutes of Health,, Baltimore, MD, June 4-6, 1986
136 Hashmat AI, Abraham J. Papaverine induced priapism, a lethal complication J Urol 1987 137:
137 Zorgniotti AW. Pharmacologic injection therapy Sem Urol 1986 4: 233 235
138 Balducci L, Phillips DM, Gearhart JG, et al. Sexual complications of cancer treatment Am Fam Practitioner 1988 37: 159 171
139 Padma-Nathan H, Goldstein I, Krane RJ. Treatment of prolonged or priapistic erections following intracavernosal papaverine therapy Sem Urol 1986 4: 236 238
140 Baum N. Treatment of impotence. I. Nonsurgical methods Postgrad Med 1987 81: 133 136
141 Trapp JD. Pharmacologic erection program for the treatment of male impotence South Med J 1987 80: 426 427 2436316
142 Halsted DS, Weigel JW, Noble MJ, el al. Papaverine-induced priapism, two case reports J Urol 1986 136: 109 110 3712593
143 Desai KM, Gingell JC, Floyd KJ. Preliminary report of a new concept in the pharmacological treatment of erectile impotence using an implantable drug delivery system Br J Urol 1987 70: 267 270
144 Ottesen B, Wagner G, Virag R, et al. Penile erection: Possible role for vasoactive intestinal polypeptide as a neurotransmitter Br Jed J 1984; 288: 9 11
145 Porst H. Value of prostaglandin E(1). in the diagnosis of erectile dysfunction in comparison with papaverine and papaverine/phentolamine in 61 patients with erectile dysfunction Urologe 1988 2: 22 26
146 Gregory JG. Impotence: The surgical approach Surg Clin N Amer 1982 62: 981 998 6758155
147 Pierini AA, Nusivmovich Nusimovich B. Male diabetic sexual impotence: Effects of dopaminergic agents Arch Androl 1981 6: 347 350 6788008
148 Muir JW, Besser GM, Edwards CRW, et al. Bromocriptine improves reduced libido and potency in men receiving maintenance hemodialysis Clin Nephrol 1983 20: 308 314 6357576
149 Lal S, Loryea Laryea E, Thovundayil J, et al. Apomorphine-induced penile tumescence in impotent patients --preliminary findings Prog Neuro Psychopharmacol Biol Psychiat 1987; 11: 235 242
150 March CM. Bromocriptine in the treatment of hypogomadismhypogonadism and male impotence Drugs 1979 17: 349 358 378650
151 Bommen Bommer J, Ritz E, del Pozo E, et al. Improved sexual function in male hemodialysis haemodialysis patients on bromocriptine Lancet 1979; 2: 496 497
152 Gwinup G. Oral phentolamine in nonspecific erectile insufficiency Ann Int Med 1988 109: 162 163 3382107
153 Mudd JW. Impotence responsive to glyceryl trinitrate Am J Psych 1977 134: 922 925
154 Editorial. Yohimbine: Time for resurrection? Lancet 1986 2: 1194 1195
155 Reid K, Morales A, Harris C, et al. Double-blind trial of yohimbine in treatment of psychogenic impotence Lancet 1987 2: 421 423
156 Morales A, Condra M, Owen JA, et al. Is yohimbine effective in the treatment of organic impotence? Results of a controlled trial J Urol 1987 13: 1168 1172 3295302
157 Nadig PW, Ware JC, Blumoff R. Noninvasive device to produce and maintain an erection-like state Urol 1986 27: 126 131 3946035
158 Whitehead ED. Diabetes-related impotence and its treatment in the middle-aged and elderly: Part II Geriatrics 1987 42: 77 85
159 Witherington R. Suction device therapy in the management of erectile impotence Urol Clin N Amer 1988 15: 123 128
160 Korenman SG, Viosca S, Griner B. Use of ErecAid in the management of erectile impotence. Abstract submitted to 1988 meeting of the Endocrine Society.
161 [no authors listed] Personal communication Veterans Administration Marketing , Center, Hines, Illinois.
162 Fenemore J, Morales A, Condra M, et al. The failure of cystometry as a diagnostic aid in impotence Neurol Urodynam 1983 2: 219 223
163 Karacan I, Moore CA. Nocturnal penile tumescence: An objective diagnostic aid for erectile dysfunction in Bennett AH (Ed): Management of Male Impotence Baltimore: Williams and Wilkins, 1982 pp. 62 72
164 Brindley GS. Maintenance treatment of erectile impotence by cavernosal unstriated muscle relaxant injection Br J Psych 1986 149: 210 215
165 Buvat J, Buvat-Herbaut M, Dehoene JL, et al. Is intracavernous injection of papaverine a reliable screening test for vascular impotence? J Urol 1986 135: 476 478
166 Streem SB. The endocrinology of impotence in Bennett AH (Ed): Management of Male Impotence, Baltimore: Williams and Wilkins, 1982 pp. 26 45
167 Zorgniotti AW, Fossi Rossi G, Padula G. Diagnosis and therapy of vasculogenic impotence J Urol 1980 123: 674 677 7420554
168 Federal Register Federal Register, March 19, 1987 52; 8648 8649
169 A.A. Sidi, MD. Personal communication. , The University of Minnesota, Department of Urologic Surgery, 1988.
170 I. Karacan, M.D. and M. Hirshkowitz, Ph.D. Personal communication. The Baylor University Sleep Disorder and Research Center, 1988
171 A. Morales, M.D. Personal communication. , The Queens University, Department of Urology, 1988