# References

1 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services, 2nd ed, Washington, DC: Office of Disease Prevention and Health Promotion 1996 190016
2 Eden KB, Orleans TC, Mulrow CD, Pender NJ, Teutsch SM. Counseling by clinicians: does it improve physical activity: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;137:208-15. [pmid: 12160371].
3 U.S. Department of Health and Human Services. Healthy People 2010, conference edition, Washington DC: U.S. Department of Health and Human Services; 2000. Available athttp://www.health.gov/healthypeople/Document/HTML/Volume2/22Physical.htmAccessed May 30, 2002
4 U.S. Department of Health and Human Services. Physical Activity and Health: A Report of the Surgeon General, Atlanta, , GA: . U.S. Department of Health and Human Services, Centers for Disease Control and Prevention. National Center for Chronic Disease Prevention and Health Promotion; 1996. Available athttp://www.cdc.gov/nccdphp/sgr/pdf/sgrfull.pdfAccessed May 30, 2002
5 Task Force on Community Preventive Services. Recommendations to increase physical activity in communities Am J Prev Med 2002 22(4S) 67 72 Available athttp://www.thecommunityguide.org/home_f.htmlAccessed June 7, 2002 11985935 166619
6 The Writing Group for the Activity Counseling Trial Research Group. Effects of physical activity counseling in primary care: The activity counseling trial: a randomized controlled trial. JAMA. 2001;286:677-87. [pmid: 11495617].
7 Francis K.T. Status of the year 2000 health goals for physical activity and fitness. Phys Ther. 1999;79(4):405-14. [pmid: 10201546]. [pmcid: 16366].
8 National Center for Health Statistics. Healthy People 2000 Review 1997, Hyattsville, , MD: . Public Health Service; 1997. DHHS Publication No. (PHS) 98-1256
9 Whitlock EP, Orleans CT, Pender N, Allan J. Evaluating primary care behavioral counseling interventions: an evidence-based approach. AJPM. 2002;22(4):267-84. [pmcid: 166619].
10 Burton LC, Paglia MJ, German PS, Shapiro S, Damiano AM. The effect among older persons of a general preventive visit on three health behaviors: smoking, excessive alcohol drinking, and sedentary lifestyle. The Medicare Preventive Services Research Team. Prev Med. 1995;24(5):492-97. [pmid: 8524724]. [pmcid: 185821].
11 Goldstein MG, Pinto BM, Marcus BH, et al. Physician-based physical activity counseling for middle-aged and older adults: a randomized trial. Annals of Behavioral Medicine. 1999;21(1):40-7. [pmcid: 226593]. [pmid: 18425653].
12 Kerse NM, Flicker L, Jolley D, Arroll B, Young D. Improving the health behaviours of elderly people: randomised controlled trial of a general practice education programme. BMJ. 1999;319(7211):683-7. [pmid: 10480825]. [pmcid: 28221].
13 Norris SL, Grothaus MA, Buchner DM, Pratt M. Effectiveness of physician-based assessment and counseling for exercise in a staff model HMO. Prev Med. 2000;30:513-23. [pmid: 10901494]. [pmcid: 194337].
14 Steptoe A, Doherty S, Rink E, Kerry S, Kendrick T, Hilton S. Behavioural counseling in general practice for the promotion of healthy behaviour among adults at increased risk of coronary heart disease: randomised trial. BMJ. 1999;319(7215):943-7; discussion 947-8. [pmid: 10514155]. [pmcid: 28246].
15 Swinburn BA, Walter LG, Arroll B, Tilyard MW, Russell DG. The green prescription study: a randomized controlled trial of written exercise advice provided by general practitioners. Am J Public Health. 1998;88(2):288-91. [pmid: 9491025]. [pmcid: 19918].
16 Smith BJ, Bauman AE, Bull FC, Booth ML, Harris MF. Promoting physical activity in general practice: a controlled trial of written advice and information materials. British Journal of Sports Medicine. 2000;34(4):262-7. [pmid: 10953898]. [pmcid: 97261].
17 Albright CL, Cohen S, Gibbons L, et al. Incorporating physical activity: advice into primary care: physician-delivered advice within the activity counseling trial. Am J Prev Med. 2000;18(3):225-34. [pmid: 10722989]. [pmcid: 18592].
18 Beaulieu MD. Physical activity counseling. In: Canadian Task Force on the Periodic Health Examination Canadian Guide to Clinical Preventive Health Care, Ottawa: Health Canada; 1994 560 569 Available at: http://www.ctfphc.org/Full_Text/Ch47full.htm. Accessed May 22, 2002
19 Patrick K, Spear B, Holt K, Sofka D, eds. Bright Futures in Practice: Physical Activity, Arlington, , VA: . National Center for Education in Maternal and Child Health; 2001. Available athttp://www.aap.org/advocacy/physicalactivity.htmAccessed May 15, 2002
20 American Academy of Family Physicians. Summary of policy recommendations for periodic health examinations, revision 5.1 Available athttp://www.aafp.org/exam/PHERev5.1-1201.pdfAccessed May 22, 2002
21 American Academy Of Pediatrics: Committee on Sports Medicine and Fitness and Committee on School Health. Policy statement: organized sports for children and preadolescents (RE0052) Pediatrics 2001 107(6) 1459 62 Available athttp://www.aap.org/policy/re0052.htmlAccessed June 4, 2002 11389277 145481
22 Fletcher GF. How to implement physical activity in primary and secondary prevention: a statement for healthcare professionals from the task force on risk reduction, American Heart Association. Circulation. 1997;96:355-7. [pmid: 9236457]. [pmcid: 15140].
23 American College of Obstetrics and Gynecology. Primary and Preventive Care: Periodic Assessments. ACOG Committee Opinion 246, Washington, DC: ACOG 2000 384376