# Recommendations of Others

The Canadian Task Force on Preventive Health Care concluded that the evidence for or against a recommendation to include physical activity counseling in the periodic health examination was lacking.^18^

Many organizations and Federal agencies recommend that healthcare providers counsel individuals about physical activity; these recommendations are based on the health benefits of physical activity rather than on the effectiveness of counseling by clinicians for promoting changes in physical activity. Such organizations include the Department of Health and Human Services (Healthy People 2010),^3^ Centers for Disease Control and Prevention, National Center for Education in Maternal and Child Health (Bright Futures),^19^ American Academy of Family Physicians,^20^ American Academy of Pediatrics,^21^ The American Heart Association,^22^ and The American College of Obstetricians and Gynecologists.^23^

The Task Force on Community Preventive Services recommends individually-adapted health behavioral programs along with several other community-based interventions. The majority of the studies that demonstrate the effectiveness of these interventions were not included in the USPSTF review because they were conducted in groups outside the primary care setting or through other media.