# Discussion

Many benefits of physical activity have been identified in epidemiologic and laboratory studies. The challenge to clinicians and communities is to determine how to promote appropriate levels of regular physical activity in large segments of the population. The USPSTF and the Task Force on Community Preventive Services have addressed these issues. Whereas the USPSTF addressed the effectiveness of clinician counseling in primary care to increase physical activity, the Task Force on Community Preventive Services has addressed the effectiveness of community-based programs that target groups rather than individual patients.^5^

That Task Force found a number of interventions to be effective in promoting physical activity, including community wide campaigns, changing school-based physical education programs, improving access to places for physical activity, and individually-adapted behavior change programs. The latter programs generally recruited groups of volunteers at community sites, work sites, or schools; used group settings to set individual goals and teach skills for incorporating physical activity into daily routines; and provided reinforcement and problem-solving through phone contact or group meetings.

Although some intervention trials suggest that primary care counseling can promote increases in physical activity, the sum of studies conducted and reported to date are inadequate to determine the overall efficacy, effectiveness, and feasibility of physical activity counseling by clinicians in primary care settings. Reasons for mixed results among existing studies are not clear but involve variability in the rigor with which the interventions were delivered or evaluated, and may reflect a failure to distinguish patients who were ready to begin an exercise program from those who were not, or a lack of the most effective mix of intervention strategies.

Further studies are needed of the effects of clinician counseling on the level of physical activity in children, adolescents, and adults. The balance of benefits and harms, as well as approaches to preventing adverse effects, particularly among older adults and those less fit, needs further exploration.