# Scientific Evidence

## Epidemiology and Clinical Consequences

Observational studies show that sedentary lifestyles (little or no leisure time, household, or occupational physical activity) are associated with increased risks for many chronic diseases and conditions, including cardiovascular disease, hypertension, diabetes, obesity, and osteoporosis, and that increased levels of physical activity can reduce these risks.^3^ Despite the well-established benefits of exercise, 20 percent to 30 percent of adult Americans reported being sedentary in 1996.^4^ Only about 20 percent of adults achieved the recommended Healthy People 2010 level of moderate physical activity: 30 minutes of moderate physical activity on most days of the week. Only 15 percent of adults achieved a vigorous level of physical activity for 20-minutes on three days of the week.^2^

Physical activity counseling practices of clinicians are highly variable. In a 1992 survey, 40 percent of internists reported assessing the activity status of patients, but only 25 percent of all the internists reported writing physical activity plans for patients.^7,8^ Similarly, 30 percent of nurse practitioners reportedly assessed the physical activity levels of patients, but only 14 percent of all the nurse practitioners provided written exercise plans.^7,8^ In a survey conducted in 1997, 42 percent of adult respondents reported receiving advice from their primary care providers to increase physical activity levels.^2^ However, the validity of such patient estimates are limited because the studies from which they were derived used varied and unclear definitions of "clinician counseling" or relied on patient recall of physical activity counseling previously received in the primary care setting.

## Effectiveness of Counseling

The ideal evidence in support of counseling would directly link counseling to improved health outcomes in a controlled trial. In the absence of such evidence, the clinical logic behind counseling is based on a series of critical assumptions:

- The clinician must be able to assess whether a patient is sedentary or physically active.
- The clinician uses critical components of counseling that must be routinely replicable among patients.
- Counseling must increase and maintain physical activity among sedentary patients.
- The benefits of this increase in physical activity must be greater than any adverse effects of assessment, counseling, and increased activity.

Several theories are available on which to build counseling interventions; many of the studies examined by the USPSTF reported using more than one theory.^9^ Most behavioral counseling strategies developed and tested for routine use by primary care providers seek to condense a more intensive, clinic-based, cognitive-behavioral intervention into a brief intervention that fits readily into routine primary care. Physical activity counseling interventions often include a single 3-5 minute encounter with the clinician, followed for some by a followup session with either the clinician or another member of the health care team. Such counseling may occur alone or in the context of preventive clinical screenings and other lifestyle behavior change interventions. In most reports, the details of the counseling intervention were incomplete. It was thus difficult to determine whether a specific counseling component was significant or essential to changing behavior. There were too few studies available or of acceptable quality to determine whether a particular counseling technique outperformed others in producing behavior change.

The USPSTF found eight fair-to-good quality controlled trials (seven randomized,^6,10-15^ and one not randomized ^16^) and five poor quality trials that addressed whether counseling involving a primary care clinician improved physical activity. Most trials involved sedentary adults. Most studies directly tested whether physical activity counseling in the primary care setting was beneficial, although some^10,12,14^ were designed to test whether educating clinicians to provide physical activity counseling was beneficial. Some interventions addressed multiple behaviors (smoking, alcohol use, and sedentary behaviors). Reports often provided limited detail regarding counseling interventions, and in several studies, delivery or receipt of the intervention was not confirmed. Some trials studied selected patient and/or provider populations. Most fair-to-good quality trials followed participants for at least 6 to 12 months and had followup rates of > 85 percent. Few studies included efforts to verify or validate self-reported behavioral outcomes.

The six trials of fair to good quality that compared physical activity counseling protocols to usual care provided mixed results.^10-14,16^ Of the three trials reporting short-term (< 6 months) behavioral outcomes, one found significantly higher physical activity levels in the intervention group, and two found no differences between intervention and control groups in activity levels. Of the six trials that reported long-term (≥ 6 months) behavioral outcomes, two found significantly higher physical activity levels in the intervention group, and four found no differences between intervention and control groups in levels of physical activity.

Two fair to good quality randomized trials compared two or more different interventions aimed at increasing physical activity.^6,15^ In one, patients receiving advice and an exercise prescription were significantly more active at 6 weeks than those receiving only advice.^15^ The second trial compared increasingly intensive interventions delivered over a 2-year period.^6^ The intervention groups in this study included: physician advice alone totaling about 18 minutes; physician advice plus moderate intensity health educator behavioral counseling totaling about 3 hours; and physician advice plus more intensive health educator behavioral counseling totaling about 9 hours. The study did not find any significant overall group differences in self-reported physical activity or cardio-respiratory fitness at 6, 12, and 24 months. However, women in the most intensively counseled group reported significantly higher energy expenditure at 6 months than women in the moderate intensity counseling and advice-only groups, and women in the moderate and intensive counseling groups were documented to have significantly higher fitness levels at 24 months (measured by V02 max) than women in the advice-only group.

The USPSTF found no completed studies examining the effectiveness of physical activity counseling for children or adolescents that compared treatment to a usual care control. Several such studies are in progress.

## Potential Adverse Effects of Counseling

Only one of the trials reviewed, monitored, and reported potential harms related to physical activity counseling.^6^ This trial, in which initially sedentary program participants between 35 and 75 years of age chose either moderate or vigorous activity, found an approximate 60 percent rate of musculoskeletal injuries and 30 percent rate of symptoms that may represent cardiovascular problems (chest pain, difficulty breathing, dizziness or loss of consciousness) over 2 years, with no significant differences between groups randomized to physician advice, physician advice plus behavioral counseling, or physician advice plus more intensive counseling. As this trial did not have a control group that received currently recommended care, it is difficult to ascertain whether any of the reported harms were directly due to physical activity counseling.

Widespread implementation of counseling could increase demand on clinical staff. However, available evidence suggests that clinicians may view counseling as a benefit to their practices. In a large randomized controlled trial, 63 percent of participating clinicians reported that counseling caused little to no increase in the length of the routine visit, 33 percent reported there was some increase, and only 4 percent complained of a substantial increase in the length of patient visits. Most clinicians (83 percent) felt that offering physical activity counseling was a benefit to the clinic.^17^