# References

1 Pignone M, Rich M, Teutsch SM, Berg AO, Lohr KN. Screening for colorectal cancer in adults at average risk: summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;137:132-41. [pmid: 12118972].
2 Pignone M, Rich M, Teutsch SM, Berg AO, Lohr KN Screening for colorectal cancer in adults. Systematic Evidence Review No. 7 (Prepared by the Research Triangle Institute-University of North Carolina Evidence-based Practice Center under Contract No. 290-97-0011). AHRQ Publication No. 02-S003, Rockville, MD. Agency for Healthcare Research and Quality June 2002 Available on the AHRQ Web site at www.ahrq.gov/clinic/serfiles.htm
3 Winawer SJ, Fletcher RH, Miller L, Godlee F, Stolar MH, Mulrow CD et al. Colorectal cancer screening: clinical guidelines and rationale. Gastroenterology. 1997;112:594-642. [pmid: 9024315].
4 Ries LA, Wingo PA, Miller DS, et al. The annual report to the nation on the status of cancer, 1973-1997, with special section on colorectal cancer. Cancer. 2000;88:2398-2424. [pmid: 10820364].
5 Stryker SJ, Wolff BG, Culp CE, Libbe SD, Ilstrup DM, MacCarty RL. Natural history of untreated colonic polyps. Gastroenterology. 1987;93:1009-13. [pmid: 3653628]. [pmcid: 276548].
6 Winawer SJ and Shike, M Prevention and control of colorectal cancer. In: Greenwald P.; Kramer BS; Weed DL, eds Cancer Prevention and Control, New YorkMarcel-Dekker 1995 pp. 537 60
7 Yamamoto M, Nakama H. Cost-effectiveness analysis of immunochemical occult blood screening for colorectal cancer among three fecal sampling methods. Hepatogastroenterology. 2000;47(32):396-99. [pmid: 10791199]. [pmcid: 87519].
8 Ransohoff DF, Lang CA. Screening for colorectal cancer with the fecal occult blood test: a background paper. American College of Physicians. Ann Intern Med. 1997;126(10):811-22. [pmid: 9148658]. [pmcid: 191867].
9 Mandel J, Bond J, Church T, Snover D, Bradley M, Schuman L, et al. Reducing mortality from colorectal cancer by screening for fecal occult blood. N Engl J Med. 1993;328:1365-71. [pmid: 8474513].
10 Hardcastle J, Chamberlain J, Robinson M, Moss S, Amar S, Balfour T, et al. Randomised controlled trial of fecal-occult-blood test. Lancet. 1996;348:1472-77. [pmid: 8942775].
11 Kronborg O, Fenger C, Olsen J, Jorgensen D, Sondergaard O. Randomised study of screening for colorectal cancer with fecal-occult-blood test. Lancet. 1996;348:1467-71. [pmid: 8942774].
12 Atkin WE, Hart A, Edwards R, McIntyre P, Aubry R, Wardle J et al. Uptake, yield of neoplasia, and adverse effects of flexible sigmoidoscopy screening. Gut. 1998;42:560-65. [pmid: 9616321]. [pmcid: 244057].
13 Lehman GA, Buchner DM, Lappas JC. Anatomical extent of fiberoptic sigmoidoscopy. Gastroenterology. 1983;84:803-8. [pmid: 6825990]. [pmcid: 277962].
14 Winawer SJ, Stewart ET, Zauber AG, Bond JH, Ansel H, Waye JD, et al. A comparison of colonoscopy and double-contrast barium enema for surveillance after polypectomy. N Engl J Med. 2000;342:393-97.
15 Rex DK, Cutler CS, Lemmel GT, Rahmani EY, Clark DW, Helper DJ, et al. Colonoscopic miss rates of adenomas determined by back-to-back colonoscopies. Gastroenterology. 1997;112:24-8. [pmid: 8978338].
16 Mandel JS, Church TR, Ederer F, Bond JH. Colorectal cancer mortality: effectiveness of biennial screening for fecal occult blood. J Natl Cancer Inst. 1999;91:434-37. [pmid: 10070942]. [pmcid: 209509].
17 Selby J, Friedman G, Quesenberry C, Weiss N. A case-control study of screening sigmoidoscopy and mortality from colorectal cancer. N Engl J Med. 1992;326:653-57. [pmid: 1736103].
18 Newcomb PA, Norfleet RG, Storer BE, Surawicz TS, Marcus PM. Screening sigmoidoscopy and colorectal cancer mortality. J Natl Cancer Inst. 1992;84:1572-75. [pmid: 1404450].
19 Winawer S. Screening for colorectal cancer with fecal occult blood testing and sigmoidoscopy. J Natl Cancer Inst. 1993;85:1311-18. [pmid: 8340943].
20 Winawer SJ, Zauber AG, Ho MN, O'Brien MJ, Gottlieb LS, Sternberg SS, et al. Prevention of colorectal cancer by colonoscopic polypectomy. The National Polyp Study Workgroup. N Engl J Med. 1993;329:1977-81. [pmid: 8247072].
21 Muller AD, Sonnenberg A. Protection by endoscopy against death from colorectal cancer. A case-control study among veterans. Arch Intern Med. 1995;155:1741-48. [pmid: 7654107].
22 Nelson RL, Abcarian H, Prasad ML. Iatrogenic perforation of the colon and rectum. Dis Colon Rectum. 1982;25:305-8. [pmid: 7083975]. [pmcid: 265888].
23 Blakeborough A, Sheridan MB, Chapman AH. Complications of barium enema examinations: a survey of UK Consultant Radiologists 1992 to 1994. Clin Radiol. 1997;52:142-48. [pmid: 9043049]. [pmcid: 203416].
24 Lieberman DA, Weiss DG, Bond JH, Ahnen DJ, Garewal H, Chejfec G. Use of colonoscopy to screen asymptomatic adults for colorectal cancer. Veterans Affairs Cooperative Study Group 380. N Engl J Med. 2000;343:162-68. [pmid: 10900274].
25 Imperiale TF, Wagner DR, Lin CY, Larkin GN, Rogge JD, Ransohoff DF. Risk of advanced proximal neoplasms in asymptomatic adults according to the distal colorectal findings. N Engl J Med. 2000;343:169-74. [pmid: 10900275].
26 Woolf SH. The best screening test for colorectal cancer-a personal choice. N Engl J Med. 2000;343:1641-3. [pmid: 11096175].
27 Byers T, Levin B, Rothenberger D, Dodd GD, Smith RA. American Cancer Society guidelines for screening and surveillance for early detection of colorectal polyps and cancer: Update 1997. American Cancer Society Detection and Treatment Advisory Group on Colorectal Cancer. CA Cancer J Clin. 1997;47(3):154-60. Available at: www.cancer.org/cancerinfo/documents/cancer_10/guidelines.html. [pmid: 9152173]. [pmcid: 19588].
28 Goldstein MM, Messing EM. Prostate and bladder cancer screening. J Am Coll Surg. 1987;186(1):63-74. Available at: www.facs.org/dept/jacs/articles/messing.html. [pmcid: 253961]. [pmid: 9449601].
29 American College of Obstetricians and Gynecologists Primary and preventive care: periodic assessments. ACOG Committee Opinion 246, Washington, DCACOG 2000 384376
30 American Academy of Family Physicians. Summary of policy recommendations for periodic health examination. Revision 5.0, August. 2001. Order No. 962, Reprint No. 510. Available at: www.aafp.org/exam/. [pmcid: 320826].
31 Solomon MJ, McLeod RS. Preventive health care, 2001 update. Colorectal cancer screening: recommendations statement. Canadian Task Force on the Periodic Health Examination. CMAJ. 2001;15(10):647-60. [pmcid: 33179].