# Recommendations of Others

The American Cancer Society recommends screening people at average risk for colorectal cancer beginning at 50 years of age by:

1. FOBT annually.
2. Flexible sigmoidoscopy every 5 years.
3. Annual FOBT plus flexible sigmoidoscopy every 5 years.
4. Double-contrast barium enema every 5 years.
5. Colonoscopy every 10 years.^27^

The American Cancer Society does not recommend DRE as a stand-alone screening test for colorectal cancer. Similar recommendations are issued by the American College of Surgeons, the American College of Obstetricians and Gynecologists, and the American Academy of Family Physicians.^28-30^ The American Gastroenterological Association, as part of a consortium of related professional organizations, also issues similar recommendations, which are currently being updated.^3^ The American College of Physicians-American Society of Internal Medicine does not have current guidelines on screening.^5^ The Canadian Task Force on Preventive Health Care concludes that there is good evidence to recommend annual or biennial FOBT and fair evidence to recommend sigmoidoscopy as part of the periodic health examination in average-risk adults after age 50 years; evidence is insufficient to recommend for or against colonosopy or combined FOBT and sigmoidscopy.^31^