# References and Notes

1 U.S. Preventive Services Task Force. Guide to clinical preventive services, 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion, U.S. Government Printing Office, 1996.
2 Nelson HD, Helfand M Screening for chlamydial infection Am J Prev Med 2001 20suppl 395 107 11306238
3 Nelson HD, Saha S. Screening for chlamydial infection. Systematic evidence review. Pub. No. AHRQ 01-S003. Rockville, MD: Agency for Healthcare Research and Quality, 2001.
4 Davies HD, Wang EEL. Periodic health examination, 1996 update: 2. Screening for chlamydial infections. CMAJ. 1996;154:1631-1644. [pmid: 8646651].
5 Centers for Disease Control and Prevention. Recommendations for prevention and management of Chlamydia trachomatis infections. MMWR Morb Mort Wkly Rep. 1993;42:1-39. [pmcid: 321737].
6 American College of Obstetricians and Gynecologists, ACOG Committee on Primary Care. Committee Opinion No. 229. Washington DC: American College of Obstetricians and Gynecologists, 1999.
7 National Committee for Quality Assurance. HEDIS 2000: The health plan employer data and information set. Volume 1: Narrative-What's in it and why it matters. Washington, DC: National Committee for Quality Assurance, 2000.