# Discussion

The introduction of sensitive, easy-to-use tests has increased the primary care physician's ability to incorporate screening for chlamydial infection into the routine care of younger women, and there is now good evidence that screening can produce important clinical benefits. Important gaps remain, however, in the information needed to guide screening in the primary care setting. Both benefits and cost-effectiveness of screening increase with the prevalence of infection, which varies markedly between communities. There is no agreement, however, on the precise prevalence that justifies screening. Clinical strategies to identify women at risk need to balance feasibility and specificity: more detailed risk assessments may yield more specific information but be harder to implement than asking questions about age and marital status. Moreover, better data on the prevalence and incidence of infection in community practice are needed to develop optimal strategies for screening in a general practice.

The advent of urine-based tests allows for routine specimen collection without a pelvic examination that may increase acceptability to patients and providers. Urine screening has also spurred interest in screening young men. Asymptomatic young men are an important reservoir for infection and are less likely than women to be detected in the course of usual care. Whether targeting men will be an effective and cost-effective strategy for reducing the burden of disease in women will depend on additional factors that have not been adequately studied, including compliance with therapy, referral of female partners, infectivity of asymptomatic men, and rates of reinfection following treatment. Trials are underway to assess the role of screening men as one strategy for controlling chlamydial infection.