# Recommendations of Others

The Canadian Task Force on Preventive Health Care (4) recommends that all members of high-risk groups be screened for chlamydial infection. The CDC (5) recommends at least routine annual screening for sexually active women under age 20 and for women aged 20-24 who meet either of the following criteria: inconsistent use of a barrier contraceptive or more than one sexual partner during the last 3 months, women older than age 24 who meet both criteria of inconsistent use of a barrier contraceptive and more than one sexual partner during the past 3 months. The American College of Obstetricians and Gynecologists (6) recommends routine screening for chlamydial infection for all sexually active adolescents and other asymptomatic women at high risk for infection. In 2000, annual chlamydia screening of sexually active women between the ages of 15 and 25 years was added to the National Committee for Quality Assurance Health Plan Employer Data and Information Set (HEDIS) (7) quality measures.