# Practice and Policy Considerations

Evaluation of cost-effectiveness of a specific screening strategy considers test performance, cost, treatment and disease outcomes, prevalence of infection in the screened population, and other factors. The USPSTF identified eight cost-effectiveness or cost-benefit analyses that examined screening in nonpregnant and pregnant women. These analyses suggest that screening may be cost-saving when conducted among nonpregnant women who are at moderate to high risk of chlamydial infection. These studies also suggest that selective screening is more likely to be cost-effective than universal screening, and that less expensive and more sensitive DNA or RNA tests would improve cost-effectiveness when compared with culture. However, because of inconsistencies in methodology and assumptions made in these cost analyses, the USPSTF concludes that available evidence on cost-effectiveness is insufficient to guide specific screening recommendations. An interactive model that allows clinicians to compare the cost-effectiveness of different screening strategies is available at www.cdc.gov/nchstp/dstd/HEDIS.htm.